# Information Technology

Using Specialized Information Technology to Reduce Errors in Emergency Cardiac Care

Improving Patient Safety with the Military Electronic Health Record

Decision Support System Design and Implementation for Outpatient Prescribing: The Safety in Prescribing Study

Looking for Trouble in All the Right Places: The Legal Implications Associated with “Electronic Signatures” and High-risk Clinical Situations

Clinical Informatics and Its Usefulness for Assessing Risk and Preventing Falls and Pressure Ulcers in Nursing Home Environments

Barriers Associated with Medication Information Handoffs