# Peer Reviewers—Volume 4

The editors thank the following individuals for serving as peer reviewers for manuscripts submitted for publication in Volume 4 of Advances in Patient Safety: New Directions and Alternative Approaches.

William Baine

David Ballard

Robert Borotkanics

Jeff Brady

Mark Bruley

Felicia Cerbone

Jay Crowley

Prashila Dullabh

W. Sherman Edwards

Janet Firshein

Marvin Fried

Darryl Gray

Dana Marie Grzybicki

Christine Hartmann

Kerm Henriksen

Ben-Tzion Karsh

Alene Kennedy

Christopher Landrigan

Kate Lapane

Kathryn Leonhardt

James Levett

David Lewin

Adil Moiduddin

Jacqueline Moss

Melinda Muller

Caitlin Oppenheimer

Jayant Pinto

Brian J. Quilliam

Judy Sangl

Lauren Silver

Ron Stock

Mike Tilkin

Jeff Weinfeld

Tong Yang