# Risk of Concurrent Use of Prescription Drugs with Herbal and Dietary Supplements in Ambulatory Care

Introduction: Little is known about the prevalence of herbal and dietary supplement (HDS) use among ambulatory patients who use prescription medications or about the risk of adverse drug events (ADEs) related to drug-HDS interactions. Methods: We conducted a secondary analysis of a study of patients who received prescription medications at four primary care practices. We used chart reviews and patient interviews to identify potential drug-HDS interactions, and we used MICROMEDEX to classify interactions. Results: A total of 101 of 657 patients (15.4 percent) reported using HDS, including echinacea (21.8 percent), ginkgo biloba (13.9 percent), glucosamine (13.9 percent), omega-3 fatty acids (12.9 percent), garlic (7.9 percent), St. John’s wort (6.9 percent), and ginseng (6.9 percent). Although we found no increased rate of ADEs among HDS users compared to nonusers, 14 percent of users had potentially dangerous interactions with their prescription drugs. Conclusion: HDS use is common in adult ambulatory care. The risk of interactions between these agents and prescription medications is worrisome.

## Introduction

In 1994, Congress defined a dietary supplement as a product taken by mouth that contains a “dietary ingredient” intended to supplement the diet. The “dietary ingredients” in these products may include vitamins, minerals, herbs or other botanicals, amino acids, and substances, such as enzymes, organ tissues, glandulars, and metabolites. Dietary supplements can also be extracts or concentrates, and they may be found in forms such as tablets, capsules, softgels, gelcaps, liquids, and powders.1

The use of herbal and dietary supplements (HDS) has grown rapidly in the United States. In 2001, consumers spent $17.8 billion on dietary supplements, including $4.2 billion of this amount for herbs.2 A comparison of the results of the National Health Interview Survey in 2002 with a 1997 survey of complementary and alternative medicine use3, 4 found a 50 percent increase in Americans’ use of herbal supplements, from 12.1 percent of adults in 1997 to 18.6 percent—or 38 million individuals—in 2002.^3^

Most dietary supplements are unlicensed, and manufacturers are not required to demonstrate efficacy, safety, or quality.5 Although herbs are often promoted as natural and therefore harmless, they are not free of adverse effects. An observational study showed that herbal supplements are associated with adverse events of all levels of severity and affect all age groups.6 As the use of herbal medicine increases, so have reports of adverse drug events (ADEs) related to HDS. To date, research regarding drug-herb interactions is limited mostly to case reports and a few systematic reviews.7, 8, 9, 10, 11, 12

Despite concerns about possible harmful interactions between prescription drugs and HDS, little is known about the concurrent use of these products by ambulatory patients. Only one published study has investigated the potential prevalence of ADEs associated with HDS in ambulatory care settings.

This study showed that 43 percent of patients seeking care at two Veterans Health Administration hospitals were taking at least one dietary supplement (including herbs, vitamins, and minerals) with prescription medications, and 45 percent had the potential for a significant drug-dietary supplement interaction.13

Because 60 to 70 percent of complementary and alternative medicine users do not discuss their use with a physician,4 patients may have few opportunities to learn about potential interactions of herbal and non-HDS with their prescription medications. To increase understanding of HDS risk and to inform clinical practice, we conducted a secondary analysis of a study of ADEs among primary care patients.14 The goals of the present study were to calculate the prevalence of HDS use among primary care patients taking prescription medications and examine the risk of drug-HDS interactions in this population.

## Methods

### Definition

We defined an ADE as an injury resulting from medical intervention related to a drug.15 We interpreted this definition to include injuries resulting from an herbal or non-HDS and from a drug-HDS interaction.

### Study Sites

We studied four Boston adult primary care practices affiliated with a teaching hospital. Two practices were located at the hospital, and two were community-based. One of each type of practice used a basic computerized system for prescribing drugs, but there was no automatic drug allergy or interaction alert feature. The other practices used handwritten paper prescriptions.

The study protocol has been described in detail and reported elsewhere.14 Briefly, study subjects included 661 adult patients who received prescription medications from internists at the study sites. All patients who received a prescription from participating physicians at an appointment were enrolled once during a 4-week enrollment period at each site. Patients were excluded if they were too ill to participate, hard of hearing, or unable to speak English or Russian. Data were collected from September 1999 through March 2000. The Beth Israel Deaconess Medical Center institutional review board approved the study in advance.

### Data Collection

One day after the patient’s appointment, investigators sent patients a letter that described the study and requested their participation in a telephone survey. Ten to 14 days after the appointment, patients who agreed to participate were asked about medication-related symptoms and to read aloud their prescription bottle labels. Patients were also interviewed 3 months after the appointment regarding their symptoms. Patients were asked at 10 days and again at 3 months if they “regularly took any nonprescription drugs, such as herbal and other dietary supplements.”

Three months after the appointment, a nurse examined subjects’ medical records to identify any ADEs, drug allergies, comorbidities, demographic characteristics, number of medications, and duration of continuous care at the practice site.

Two physicians then reviewed the chart and survey data to ascertain the presence of ADEs. Physician reviewers attributed none of the ADEs of the original study to an HDS. However, the investigators did not evaluate the presence of potential ADEs related to drug-HDS interactions.

For the present study, we identified potential drug-HDS interactions by reviewing each patient’s medication list. Interactions were classified according to the DRUG-REAX^®^ system database from MICROMEDEX, which was available to clinicians at the four practice sites.16 Potential drug-HDS interactions were classified by MICROMEDEX as “minor,” “moderate,” or “major” as follows:

Major: The interaction may be life-threatening and/or require medical intervention to minimize or prevent serious adverse effects.

Moderate: The interaction may result in an exacerbation of the patient’s condition and/or require an alteration in therapy.

Minor: The interaction would have limited clinical effects. Manifestations may include an increase in the frequency or severity of side effects but generally would not require a major alteration in therapy.

If we identified a potential drug-HDS interaction, we used two additional databases to confirm the reported interaction from MICROMEDEX.17, 18 In all cases, the three databases gave consistent results.

### Statistical Analyses

We used Student’s t-test and the chi-square statistic for continuous and categorical variables, respectively. Reported P values are based on two-tailed tests of significance. Logistic regression was used to examine factors associated with patients’ use of any HDS. The model was adjusted for patient and practice attributes (i.e., age, sex, primary language other than English, ethnicity, years of education, type of practice, type of prescribing, number of medications, and duration of clinic care) found to be associated with ADEs in the original study.14 A dichotomous variable for HDS use was included in the final model. SAS^®^ (SAS Institute) version 8e was used for statistical analyses.19

## Results

### Herbal/Dietary Supplement Use

Of 1,202 potentially eligible patients in the original study, 661 (55 percent) completed the initial telephone survey and were enrolled. Of enrolled patients, 600 (91 percent) completed the telephone survey at 3 months. Chart reviews were completed for 653 patients (99 percent). We analyzed 657 of 661 potentially eligible patients for the present study because four patients did not answer the question regarding the use of herbal and other dietary supplements.

Of the 657 patients, 101 (15.4 percent) reported using at least one HDS (Table 1). Overall, patients used 39 different supplements. The most commonly used herbs were echinacea (22 percent), ginkgo biloba (14 percent), St. John’s wort (7 percent), ginseng (7 percent), evening primrose oil (5 percent), and saw palmetto (4 percent). The most commonly used nonherbal dietary supplements were glucosamine (14 percent), omega-3 fatty acids (13 percent), garlic (8 percent), chondroitin (5 percent), coenzyme Q10 (5 percent), flax seed (4 percent), and cranberry (4 percent).

Table 1 Most commonly used HDS and non-HDS

Supplement | Common uses | Supplement class | No. of HDS users | % HDS users^a^ (N = 101) | % Patients (users + nonusers)^a^ (N = 657)
Any supplement | | | 101 | 100 | 15.4
Echinacea | Prevent common cold | Herbal | 22 | 21.8 | 3.3
Gingko biloba | Enhance memory and concentration | Herbal | 14 | 13.9 | 2.1
Glucosamine | Treat osteoarthritis | Nonherbal | 14 | 13.9 | 2.1
Omega-3 fatty acids | Prevent cardiovascular disease | Nonherbal | 13 | 12.9 | 2.0
Garlic | Prevent cardiovascular disease, improve hyperlipidemia | Nonherbal | 8 | 7.9 | 1.2
St. John’s wort | Antidepressant | Herbal | 7 | 6.9 | 1.1
Ginseng | Stimulant | Herbal | 7 | 6.9 | 1.1
Evening primrose oil | Treat premenstrual syndrome | Herbal | 5 | 5.0 | 0.8
Chondroitin | Treat osteoarthritis | Nonherbal | 5 | 5.0 | 0.8
Coenzyme Q10 | Various uses, including treatment of hypertension | Nonherbal | 5 | 5.0 | 0.8
Saw palmetto | Treat benign prostatic hypertrophy | Herbal | 4 | 4.0 | 0.6
Flax seeds | Prevent heart disease and cancer | Nonherbal | 4 | 4.0 | 0.6
Cranberry | Prevent heart disease and cancer, treat urine infection | Nonherbal | 4 | 4.0 | 0.6
Other^b^ | | | 24 | 23.8 | 3.7

a Totals exceed 100% because 33 patients used multiple supplements.

b Other supplements included: arnica, bilberry, bromeline, chromium picolinate, comphrey, dehydroepiandrosterone, dong quai, ginger, goldenseal, grape seed, hawthorne, herbal tea, isoflavone, kava kava, L-carnitine, lecithin, lutein, lysine, melatonin, mistletoe, niacin, pyruvate, slippery elm, vitex, wild yam.

### Subject Participation and Characteristics

Table 2 shows the characteristics of HDS users and non-users. Compared to nonusers, more users were white (88 vs. 79 percent, P = 0.04), college educated (90 vs. 80 percent, P = 0.02), English speaking (98 vs. 91 percent, P = 0.02), and had fewer than 3 years of continuous care at the practice site (44 vs. 34 percent, P = 0.09).

Table 2 Characteristics of study sample, by HDS and non-HDS use

Characteristic | Total (N = 657) | Users (N = 101) | Nonusers (N = 556) | P-value^a^
Mean age (±SD) (yrs) | 52 (16.9) | 52.5 (15.9) | 52.6 (17.1) | 0.94
Sex^b^
Male (%) | 34 | 33 | 34 | 0.82
Female (%) | 66 | 67 | 66 | 0.82
Race
White (%) | 80 | 88 | 79 | 0.04
Non-white (%) | 20 | 12 | 21 | 0.04
Primary language
English (%) | 92 | 98 | 91 | 0.02
Non-English (%) | 8 | 2 | 9 | 0.02
Education level
<12 years (%) | 18 | 10 | 20 | 0.02
≥12 years (%) | 82 | 90 | 80 | 0.02
Mean (±SD) medications | 3.6 (2.9) | 3.6 (2.7) | 3.6 (2.9) | 0.89
Years of continuous care
<3 | 36 | 44 | 34 | 0.09
≥3 | 64 | 56 | 66 | 0.09

a Student’s t-test for continuous and chi-square for categorical variables.

b Based on N = 656

In the multivariable analysis, HDS use was associated with college education [OR 2.25, 95 percent CI (1.09, 4.65)] and English speakers [OR 4.32, 95 percent CI (1.01, 18.49)] and was inversely associated with 3 years or more of continuous care [OR 0.80, 95 percent CI (0.66, 0.97)] (Table 3).

Table 3 Patient characteristics associated with HDS and non-HDS use

Characteristic | Unadjusted OR (95% CI) | Adjusted OR (95% CI)
Age (years) | 0.99 (0.99, 1.01) | 1.01 (0.99, 1.03)
Sex
Female | 0.94 (0.60, 1.48) | 0.87 (0.55, 1.40)
Male | 1.0 | 1.0
Race
White | 1.98 (1.05, 3.74) | 1.54 (0.80, 2.98)
Non-white | 1.0 | 1.0
Primary Language
English | 4.78 (1.15, 20.00) | 4.32 (1.01, 18.49)
Non-English | 1.0 | 1.0
Education level
>12 yrs | 2.24 (1.13, 4.45) | 2.25 (1.09, 4.65)
≤12 yrs | 1.0 | 1.0
No. of medications | 1.01 (0.93, 1.08) | 1.02 (0.95, 1.11)
Years of continuous care
≥3 | 0.82 (0.69, 0.98) | 0.80 (0.66, 0.97)
<3 | 1.0 | 1.0

OR = odds ratio; CI = confidence interval

### Adverse Drug Events Among Herbal and Dietary Supplement Users

Twenty-nine (29 percent) of the 101 HDS users experienced an ADE, compared to 131 (24 percent) of the 556 nonusers (P = 0.27), a nonsignificant difference in univariate and multivariate analyses.

Although we identified no ADEs attributable to drug-HDS interactions, we identified 14 patients with 25 potential drug-supplement interactions among the 101 HDS users (Table 4). Potentially serious (“major”) drug-herb interactions included St. John’s wort with selective serotonin reuptake inhibitors (SSRIs) or with oral contraceptives, and ginkgo biloba with antiplatelet agents, nonsteroidal anti-inflammatory drugs (NSAIDs), or trazodone. Two of the 14 patients had multiple potential drug-supplement interactions.

Table 4 Potential drug-HDS and non-HDS interactions

Herb | Interacting drug | No. of interactions | Interaction severity^a^ | Quality of documentation regarding interaction^a^ | Description of interaction
St. John’s wort | SSRIs | 1 | MAJOR | Fair | Increased risk of serotonin syndrome
St. John’s wort | Oral contraceptives | 2 | MAJOR | Good | Decreased contraceptive effectiveness
St. John’s wort | Benzo-diazepines | 1 | Minor | Fair | Reduced benzodiazepine effectiveness
St. John’s wort | Statins | 1 | Moderate | Fair | Reduced atorvastatin & simvastatin effectiveness
Ginkgo biloba | SSRIs | 7 | Moderate | Fair | Increased risk of serotonin syndrome
Ginkgo biloba | Antiplatelet agents^b^ | 5 | MAJOR | Fair | Increased risk of bleeding
Ginkgo biloba | NSAIDs | 2 | MAJOR | Fair | Increased risk of bleeding
Ginkgo biloba | Nifedipine | 1 | moderate | Fair | Increased risk of nifedipine side effects
Ginkgo biloba | Trazodone | 1 | MAJOR | Poor | Excessive sedation and potential coma
Ginkgo biloba | Anti-convulsants | 1 | Moderate | Fair | Decreased anticonvulsant effectiveness
Ginkgo biloba | Buspirone | 1 | Moderate | Fair | Changes in mental status
Garlic | Antiplatelet agents^b^ | 1 | Moderate | Fair | Increased risk of bleeding
Ginseng | Nifedipine | 1 | Moderate | Fair | Increased risk of nifedipine side effects

a Based on MICROMEDEX classification.

b Aspirin was the only antiplatelet agent used by supplement users.

## Discussion

We examined the use of HDS among adult ambulatory patients using prescription drugs in a secondary analysis of a study of ADEs. We found that one in six patients used at least one dietary supplement along with their prescription medications. Echinacea, gingko biloba, glucosamine, omega-3 fatty acids, and garlic were the most commonly used supplements. Compared to nonusers, users had higher levels of education, were English speakers, and had fewer years of continuous primary care. A similar percent of HDS users had an ADE compared to nonusers (29 percent vs. 24 percent), a difference that was not statistically significant. However, we found potential drug-HDS interactions among 14 of 101 patients, and many of these interactions were potentially serious or life threatening.

Although the news media have publicized cases of ADEs related to HDS,20 few prior studies have examined the prevalence of drug-HDS interactions.13, 21, 22 The rate of potential drug-HDS interactions in our study (25 percent) was greater than previous reports of drug-HDS interactions.13, 21, 22 The rate was similar to the high rate of drug-drug interactions in studies of outpatients, where researchers have reported potential ADE rates of 9.2 percent to 70.3 percent of any severity, and 1.2 percent to 23.3 percent for more serious events.23, 24, 25, 26, 27, 28, 29, 30 Our study also contributes to the literature in demonstrating that many drug-HDS interactions are potentially serious or life threatening.

How can we account for the number of potentially serious drug-HDS interactions in this study? It is possible that the commercial databases for classifying these interactions overestimate the severity of interactions, in part, because they rely on case reports to identify such events—a reporting bias. Because HDS are unregulated, rigorous premarket testing is not required, and as a result, the clinical importance of HDS-related ADEs and interactions are not well characterized. Another possibility is that HDS-drug interactions represent a serious and under-recognized hazard in clinical care. If patients and clinicians were better informed about the prevalence and potential severity of these interactions, perhaps they would be more cautious about the concurrent use of prescription or over-the-counter (OTC) medications and HDS.

Our findings regarding the prevalence of HDS use are consistent with previous studies and market data. National estimates of herb use range from 9 to 19 percent.4, 31, 32, 33, 34, 35, 36, 37, 38 National rates of concurrent use of dietary supplements and prescription medications are 16 to 18.4 percent.4, 36 Based on market data, the largest-selling herbs during 1999–2000 were ginkgo biloba, St. John’s wort, ginseng, garlic, echinacea, and saw palmetto (Information Resources, Inc. Jan 1, 1999). In the same year, ginseng, ginkgo biloba, glucosamine, St. John’s wort, and echinacea were reported to be the most commonly used HDS.36 However, our results are inconsistent with several ambulatory care studies that found rates of use of up to 57 percent.13, 21, 39, 40, 41, 42, 43, 44, 45, 46, 47, 48 Differences may be due to practice type,22 patient population,13, geographic variation,48 differing definitions of dietary supplements,13, 21 or secular trends. For example, two studies included vitamins and minerals in their definition of dietary supplements, thus accounting for a greater prevalence of reported dietary supplement use.13, 21

Like previously published national studies,31, 32, 36, 49 we also found that HDS use was common in middle age, among women, among those with more than a high school education,31, 32, 49 and with concurrent use of prescription or OTC medications.36 Our results also corroborate work showing that complementary and alternative medicine users are more likely to have a place to go for usual care, to have a customary medical care provider, and to have seen a medical professional in the past 12 months.37 All the patients in our study had a usual primary care provider, although higher HDS use was associated with less than 3 years of continuous care.

Our study offers several implications for clinical practice. First, clinicians may benefit from more effective education about HDS. Despite the widespread use of supplements, some physicians lack knowledge about HDS.50, 51, 52 Only about half of physicians in one study were able to identify potential interactions between herbs and conventional medications. Educating clinicians about herbs and dietary supplements could help reduce the chance of dangerous interactions.

Second, given the potential for interactions with conventional drugs, health professionals should ask patients about their use of HDS and non-HDS. Our findings support the Joint Commission requirement that HDS and non-HDS use be included in patients’ medication lists.

Third, electronic order entry systems should include drug-HDS alerts for potentially dangerous interactions. Given the large number of different drug-HDS combinations, physicians would benefit from the support of electronic knowledge databases that include information about the most serious drug-HDS interactions.53, 54, 55

Our study has several limitations. First, because we studied only four primary care practices, our results may not be generalizable. Our sample included many white, English-speaking, college-educated patients in an urban setting. Supplement use by other ethnic groups and in other cultures might differ. Second, we relied on patients’ self-reports of HDS use, and they may have underreported. Third, we may not have ascertained completely the contribution of HDS use to ADEs because this information may not have been recorded in the chart or elicited accurately in the patient interviews. Fourth, our study was powered to examine ADE rates in primary care practices with and without computerized order entry systems. Although we found a slightly higher rate of ADEs among HDS users than nonusers, the study had only 16 percent power to examine this association. A study with a larger sample size would allow researchers to evaluate the impact of HDS use on ADEs.

Our results suggest that the use of herbs and dietary supplements is common in adult primary care. Although we observed no increased rate of ADEs among patients using supplements compared to nonusers, we identified many potentially serious interactions between these agents and conventional medications. Improvements in eliciting information about the use of HDS and non-HDS and providing electronic decision support for interactions between supplements and medications may be important for preventing ADEs in ambulatory care.

## Acknowledgments

Dr. Graham was supported by a National Institute of Health (NIH) Institutional National Research Service Award, Grant No. T32-AT0051-03. Dr. Phillips was supported by an NIH Mid-Career Investigator Award K24-AT000589 from the National Center for Complementary and Alternative Medicine (NCCAM), NIH. Dr. Weingart was supported by a K08 Mentored Clinical Scientist Career Development Award (1 K08 HS11644) from the Agency for Healthcare Research and Quality.

This manuscript was made possible by CRICO/RMF and by Grant Number T32-AT0051-03 from NCCAM, NIH. The contents of this manuscript are solely the responsibility of the authors and do not represent the official views of the NCCAM or the NIH. The authors have no potential conflicts to disclose. We gratefully acknowledge the contribution of Dr. David M. Eisenberg, who reviewed early drafts of this manuscript.

## References

1 Dietary supplement health and education act of 1994: Pub. Law No. 103-417, 108 Stat 4325; Oct 25, 1994.
2 (2002). NBJ’s annual industry overview VII. Nutrition Business Journal.
3 Tindle H. (2005). Trends in use of complementary and alternative medicine by U.S. adults: 1997–2002. Altern Ther Health Med.
4 Eisenberg DM, Davis RB, Ettner SL, et al. (1998). Trends in alternative medicine use in the United States, 1990–1997: Results of a follow-up national survey. JAMA.
5 De Smet PA. (2002). Herbal remedies. N Engl J Med.
6 Palmer ME, Haller C, McKinney PE. (2003). Adverse events associated with dietary supplements: An observational study. Lancet.
7 Smolinske S. (1999). Dietary supplement-drug interactions. J Am Med Womens Assoc.
8 Brazier NC, Levine MA. (2003). Drug-herb interaction among commonly used conventional medicines: A compendium for health care professionals. Am J Ther.
9 Markowitz JS, DeVane CL. (2001). The emerging recognition of herb-drug interactions with a focus on St. John's wort (Hypericum perforatum). Psychopharmacol Bull.
10 Williamson EM. (2003). Drug interactions between herbal and prescription medicines. Drug Saf.
11 Izzo AA, Ernst E. (2001). Interactions between herbal medicines and prescribed drugs: A systematic review. Drugs.
12 Fugh-Berman A, Ernst E. (2001). Herb-drug interactions: Review and assessment of report reliability. Br J Clin Pharmacol.
13 Peng CC, Glassman PA, Trilli LE, et al. (2004). Incidence and severity of potential drug-dietary supplement interactions in primary care patients: An exploratory study of 2 outpatient practices. Arch Intern Med.
14 Gandhi TK, Weingart SN, Borus J, et al. (2003). Adverse drug events in ambulatory care. N Engl J Med.
15 Bates DW, Cullen DJ, Laird N, et al. (1995). Incidence of adverse drug events and potential adverse drug events. Implications for prevention. ADE Prevention Study Group. JAMA.
16 AltMedDex^®^ System [Internet database]. (2004).
17 (2004). Jellin J, editor. Natural medicines comprehensive database.
18 (2004). Basch EM, Ulbricht CE, editors. Natural standard.
19 SAS [computer program]. (2003). Version 8e.
20 Brody J. (2003). Personal health: Herbal and natural don't always mean safe. New York Times.
21 Rhee SM, Garg VK, Hershey CO. (2004). Use of complementary and alternative medicines by ambulatory patients. Arch Intern Med.
22 Dergal JM, Gold JL, Laxer DA, et al. (2002). Potential interactions between herbal medicines and conventional drug therapies used by older adults attending a memory clinic. Drugs Aging.
23 Bates DW, Yu DT. (2003). Clinical impact of drug-drug interactions with systemic azole antifungals. Drugs Today (Barc).
24 Peterson JF, Bates DW. (2001). Preventable medication errors: Identifying and eliminating serious drug interactions. J Am Pharm Assoc (Wash).
25 Jankel CA, Speedie SM. (1990). Detecting drug interactions: A review of the literature. DICP.
26 Bjorkman IK, Fastbom J, Schmidt IK, et al. (2002). Drug-drug interactions in the elderly. Ann Pharmacother.
27 Costa AJ. (1991). Potential drug interactions in an ambulatory geriatric population. Fam Pract.
28 Bergendal L, Friberg A, Schaffrath A. (1995). Potential drug-drug interactions in 5,125 mostly elderly out-patients in Gothenburg, Sweden. Pharm World Sci.
29 Rosholm JU, Bjerrum L, Hallas J, et al. (1998). Polypharmacy and the risk of drug-drug interactions among Danish elderly. A prescription database study. Dan Med Bull.
30 Bjerrum L, Andersen M, Petersen G, et al. (2003). Exposure to potential drug interactions in primary health care. Scand J Prim Health Care.
31 Bruno JJ, Ellis JJ. (2005). Herbal use among U.S. elderly: 2002 National Health Interview Survey. Ann Pharmacother.
32 Kelly JP, Kaufman DW, Kelley K, et al. (2005). Recent trends in use of herbal and other natural products. Arch Intern Med.
33 Mackenzie ER, Taylor L, Bloom BS, et al. (2003). Ethnic minority use of complementary and alternative medicine (CAM): A national probability survey of CAM utilizers. Altern Ther Health Med.
34 Graham RE, Ahn AC, Davis RB, et al. (2005). Use of complementary and alternative medical therapies among racial and ethnic minority adults: Results from the 2002 National Health Interview Survey. J Natl Med Assoc.
35 Yu SM, Ghandour RM, Huang ZJ. (2004). Herbal supplement use among U.S. women, 2000. J Am Med Womens Assoc.
36 Kaufman DW, Kelly JP, Rosenberg L, et al. (2002). Recent patterns of medication use in the ambulatory adult population of the United States: The Slone survey. JAMA.
37 Ni H, Simile C, Hardy AM. (2002). Utilization of complementary and alternative medicine by United States adults: Results from the 1999 National Health Interview Survey. Med Care.
38 Blendon RJ, DesRoches CM, Benson JM, et al. (2001). Americans' views on the use and regulation of dietary supplements. Arch Intern Med.
39 Gore A, Mills O, Gonzalez L, et al. (2002). Herbal supplement use among patients in a rural health system. Hosp Pharm.
40 Rivera JO, Ortiz M, Lawson ME, et al. (2002). Evaluation of the use of complementary and alternative medicine in the largest United States-Mexico border city. Pharmacotherapy.
41 Boutin PD, Buchwald D, Robinson L, et al. (2000). Use of and attitudes about alternative and complementary therapies among outpatients and physicians at a municipal hospital. J Altern Complement Med.
42 Wolsko P, Ware L, Kutner J, et al. (2000). Alternative/complementary medicine: Wider usage than generally appreciated. J Altern Complement Med.
43 Palinkas LA, Kabongo ML. (2000). The use of complementary and alternative medicine by primary care patients. A SURF*NET study. J Fam Pract.
44 Murray J, Shepherd S. (1993). Alternative or additional medicine? An exploratory study in general practice. Soc Sci Med.
45 Drivdahl CE, Miser WF. (1998). The use of alternative health care by a family practice population. J Am Board Fam Pract.
46 Elder NC, Gillcrist A, Minz R. (1997). Use of alternative health care by family practice patients. Arch Fam Med.
47 Eliason BC. (1996). Family medicine in Massachusetts. J Am Board Fam Pract.
48 Hernández L, Muñoz RA, Miró G, et al. (1984). Use of medicinal plants by ambulatory patients in Puerto Rico. Hosp Pharm.
49 Barnes PM, Powell-Griner E, McFann K, et al. (2004). Complementary and alternative medicine use among adults: United States, 2002. Adv Data.
50 Caspi O, Bell IR, Rychener D, et al. (2000). The Tower of Babel: Communication and medicine: An essay on medical education and complementary-alternative medicine. Arch Intern Med.
51 Murtaza M, Singh M, Dimitrov V, et al. (2001). Awareness of CAM among residents: A long way to go. Arch Intern Med.
52 Haramati A, Lumpkin MD. (2001). Integrating complementary and alternative medicine into conventional medical education: Role of basic science. Arch Intern Med.
53 Tamblyn R, Huang A, Perreault R, et al. (2003). The medical office of the 21^st^ century (MOXXI): Effectiveness of computerized decision-making support in reducing inappropriate prescribing in primary care. CMAJ.
54 Halkin H, Katzir I, Kurman I, et al. (2001). Preventing drug interactions by online prescription screening in community pharmacies and medical practices. Clin Pharmacol Ther.
55 Bates DW, Leape LL, Cullen DJ, et al. (1998). Effect of computerized physician order entry and a team intervention on prevention of serious medication errors. JAMA.