# Acknowledgments

The present Advances in Patient Safety: New Directions and Alternative Approaches, like its predecessor, Advances in Patient Safety: From Research to Implementation, contains well over a hundred patient safety papers distributed across four volumes. In undertaking a project of this scope and completing it in a timely fashion, the editors depend upon the good will, collaborative efforts, and commitment of many people, both internal and external to the Agency for Healthcare Research and Quality (AHRQ). Foremost among this group are the patient safety researchers and their teams, whose work will be found in the pages that follow. We are indebted to them for their scholarship, research skills, and willingness to share with us their conceptual schemes, empirical findings, and lessons learned in addressing significant patient safety issues. Given the breadth of content, readers are sure to find much of interest to their own work. At the same time, a large number of peer reviewers willingly gave of their time in commenting constructively on the submitted manuscripts to ensure their quality and appropriateness. A list of the peer reviewers can be found in the back of each volume.

Also in evidence throughout the entire effort were the organizing skills of Ms. Alene Kennedy, Ms. Felicia Cerbone, and their colleagues at the National Opinion Research Center (NORC) at the University of Chicago. Their assistance in keeping track of submitted manuscripts, maintaining communication with authors and reviewers, and engaging the editing skills of Dr. Lane Lenard of BioMedical Communications, Inc., is very much appreciated.

We also would like to acknowledge the support and encouragement from AHRQ’s Office of the Director, the Center for Quality Improvement and Patient Safety (CQuIPS), and the Office of Communications and Knowledge Transfer (OCKT). Within OCKT, a hearty thank you is extended to Ms. Randie Siegel and other helping hands in her Print and Electronic Publishing group. Of special note are the desktop design skills of Ms. Frances Eisel and Mr. Joel Boches. Editorial assistance was provided by Ms. Stephanie Grant of EEI Communications, Inc.

Kerm Henriksen

James B. Battles

Margaret A. Keyes

Mary L. Grady

Editors