# Tools and Practices

Developing the Tools to Administer a Comprehensive Hospital Discharge Program: The ReEngineered Discharge (RED) Program

Creating an Accurate Medication List in the Outpatient Setting Through a Patient-Centered Approach

The Use of Modest Incentives to Boost Adoption of Safety Practices and Systems

Using Data Mining to Predict Errors in Chronic Disease Care

Venous Thromboembolism Safety Toolkit: A Systems Approach to Patient Safety

Using Process Measures to Improve Patient Safety Practices to Prevent Pulmonary Embolism

A Tool to Assess Compliance in Anticoagulation Management

Using Lean Six Sigma^®^ Tools to Compare INR Measurements from Different Laboratories Within a Community

Using Six Sigma^®^ Methodology to Improve Handoff Communication in High-Risk Patients

10-Year Experience Integrating Strategic Performance Improvement Initiatives: Can the Balanced Scorecard, Six Sigma^®^, and Team Training All Thrive in a Single Hospital?

Impact of Staff-Led Safety Walk Rounds

Development of a Web-Based Patient Safety Resource: AHRQ Patient Safety Network (PSNet)