# Teamwork and Communication

TeamSTEPPS^™^: Team Strategies and Tools to Enhance Performance and Patient Safety

Understanding Quality and Safety Problems in the Ambulatory Environment: Seeking Improvement With Promising Teamwork Tools and Strategies

Building Self-Empowered Teams for Improving Safety in Postoperative Pain Management

Beyond Rapid Response Teams: Instituting a “Rover Team” Improves the Management of At-Risk Patients, Facilitates Proactive Interventions, and Improves Outcomes

Improving Referral Communication Using a Referral Tool Within an Electronic Medical Record

Improving Patient Safety Through Provider Communication Strategy Enhancements

Improving Clinical Communication and Patient Safety: Clinician-Recommended Solutions