# Simulation

In Situ Simulation: Challenges and Results

The Nature, Characteristics and Patterns of Perinatal Critical Events Teams

Failure Modes and Effects Analysis Based on In Situ Simulations: A Methodology to Improve Understanding of Risks and Failures

The Mobile Mock Operating Room: Bringing Team Training to the Point of Care

Examining the Effectiveness of Debriefing at the Point of Care in Simulation-Based Operating Room Team Training

Effect of Recent Refresher Training on in Situ Simulated Pediatric Tracheal Intubation Psychomotor Skill Performance

Simulation-Based Education Improves Patient Safety in Ambulatory Care