# Peer Reviewers—Volume 3

The editors thank the following individuals for serving as peer reviewers for manuscripts submitted for publication in Volume 3 of Advances in Patient Safety: New Directions and Alternative Approaches.

Alex Alonso

David Baker

Robert Borotkanics

Twila Burdick

Denise Burgess

Pascale Carayon

Felicia Cerbone

Sheila Chauvin

John Clarke

Katherine Crosson

Elizabeth Dayton

Noel Eldridge

Martin Erlichman

Oscar Espinosa

Marvin Fried

Jeanne-Marie Guise

Kerm Henriksen

Eileen Hogan

Brian Jack

Julie Johnson

Stephen Small

Mark Stanton

David Studdert

Eric Thomas

Patrick Toomey

John Vozenilek

Harold Kaplan

Barbara Kass

Alene Kennedy

Margaret Keyes

Heidi King

Mark Linzer

John Messenger

Melinda Muller

Vinay Nadkarni

John Paige

Cynthia Palmer

Mary Patterson

Shawna Perry

Peter Pronovost

Gina Pugliese

Deborah Queenan

Ramnaraya Paragi-Gururaja

John Reiling

F. Jacob Seagull

Lauren Silver

Robert Wears

John Webster

Seth Wolpin

Donna Woods

Tong Yang

Brenda Zierler