# Human Factors

Pillars of a Smart, Safe Operating Room

High-Hanging Fruit: Improving Transitions in Health Care

Minding the Gaps: Creating Resilience in Health Care

Error Producing Conditions in the Intensive Care Unit

Patient Monitors in Critical Care: Lessons for Improvement