# Development of a Web-Based Patient Safety Resource: AHRQ Patient Safety Network (PSNet)

Since the Institute of Medicine released its To Err Is Human report, published research and other activities related to patient safety have increased substantially. Interested stakeholders now require a resource to stay abreast of the latest news and findings. Under contract with the Agency for Healthcare Research and Quality (AHRQ), we developed a comprehensive and continuously updated Web-based portal to address this need. The AHRQ Patient Safety Network (AHRQ PSNet), launched in April 2005, features weekly updates of annotated resources, a collection of patient safety “classics,” and opportunities for users to receive weekly updates and create their own “My PSNet” option. As of July 2007, the site has more than 6,500 subscribers to the weekly newsletter and receives approximately 1.5 million yearly visits. We anticipate that the AHRQ PSNet will continue to provide important and updated safety information to a diverse array of users and to leverage the reach and scalability of the Internet.

## Introduction

The landmark Institute of Medicine report, To Err Is Human, increased public awareness about patient safety and catalyzed efforts to reduce medical errors.1 The number of stakeholders—providers, administrators, legislators, regulators, payers, and patients—continues to grow. Advances are also evidenced by the rapid growth of published research,2 the development of practical toolkits and educational curricula, the creation of safety-specific journals, and the availability of dedicated patient safety conferences.

A resulting challenge is to stay abreast of the latest patient safety literature and news. Whereas certain fields (e.g., cardiology or critical care) allow their “experts” to remain updated through a relatively narrow set of journals and conferences, patient safety experts span a variety of disparate fields. A clinician, researcher, educator, administrator, or policymaker trying to stay updated in the field might need to read a wide range of general and specialty journals in medicine, nursing, and pharmacy, as well as human factors, informatics, health policy, and law.

Recognizing the need for a comprehensive information resource for those working in patient safety, the Agency for Healthcare Research and Quality (AHRQ) issued a Request for Proposals (RFP) in July 2004 to create a “one-stop” Web-based resource for the patient safety community. Our editorial team—which comprised physicians with a strong interest and track record in patient safety and medical education, the managing editor for AHRQ Morbidity & Mortality Rounds on the Web (AHRQ WebM&M), and a library scientist and cybrarian with expertise in patient safety—partnered with a technical contractor, Silverchair (Charlottesville, VA), and we were awarded the contract.

In particular, we aimed to leverage our experience and success with AHRQ WebM&M,3 the Web-based safety journal that first combined anonymous reporting with case-based presentations and expert commentaries.4 Our goal was to build a new and innovative patient safety portal that would allow delivery of timely and highly accessible information, evidence, education, and insight to improve health care systems and patient care and create a partnership and linkage with AHRQ WebM&M to permit users to benefit from both sites’ resources.

Launched in April 2005, AHRQ’s Patient Safety Network (AHRQ PSNet) features weekly updates of annotated resources, a collection of patient safety “classics,” and opportunities for users to receive weekly e-mail updates and create their own “My PSNet” option.5, 6 In this article, we describe the development of AHRQ PSNet, summarize a number of key outcome measures based on site-user data, and discuss future directions. We hope our experiences provide useful lessons that can be applied by others dedicated to patient safety and those who may be considering the use of the Internet as a tool to disseminate health-related content to a widely dispersed, worldwide audience.

## Site Development

The contract called for a creative and engaging patient safety portal that linked to existing resources (everything from toolkits on the AHRQ Web site to resources from the Joint Commission), could generate both passive content (i.e., posted on the site) and active alerts for new content (i.e., e-mailed to registered users), and had a fully searchable set of resources.

In addition to these requirements, our goals were to develop an intuitive and attractive user experience, ensure a seamless interface with AHRQ WebM&M, create a powerful taxonomy for organizing a large number of resources, and allow extensive customization. Next, we describe the major issues and challenges in site development, including choosing content for inclusion, refining our editorial workflow, creating specific site attributes, and developing our taxonomy.

### Content Selection and Editorial Workflow

To create timely and high-quality weekly AHRQ PSNet issues, we needed a system that was fluid and dependable, could function as a content management tool, and would alert different members of the editorial team when their tasks were ready for assignment. Our technical contractor helped develop an online authoring tool that provided the necessary structure and organization to help publish our new issue every Wednesday.

Each week, our library scientist and editorial team identify potentially relevant content via systematic searches of bibliographic databases (e.g., PubMed) and also several other clinical, health care administration, business, legal, and lay press publications (e.g., newspapers and magazines). We also closely follow industry and consumer dialogue on patient safety issues via blogs, LISTSERV™ applications, and Web-facilitated news and site update alerts. Finally, our managing editor is able to anticipate inclusion of important resources in a timely manner through media access to upcoming, embargoed publications.

One of our first editorial decisions during site development focused on the number of new resources we could reliably add in a given week. We decided to choose quality over quantity, opting to provide users with editorial input into new content, rather than simply including all relevant content and potentially overwhelming users. After agreeing on a starting set of resources prior to launch (with larger input from our expert Editorial Board), we targeted inclusion of 20 to 25 new resources each week (~1,000/year) spanning journal articles, newspaper stories, conference proceedings, toolkits, and reports.

Our editorial team spotlights certain items each week by accompanying the resource with an annotated summary. These summaries (approximately 100 to 150 words) aim to highlight important information from the resource and lead users to related content, glossary items, or AHRQ WebM&M commentaries via hyperlinks. Thus, while reading an annotated summary, a user is also directed to other relevant literature elsewhere on AHRQ PSNet, a feature that enhances the user experience (Figure 1). The remaining resources receive shorter summaries with the same linking principles to create similar depth to each resource description. Evaluation of past user behavior (discussed in more detail in the Results section) has allowed us to tailor our editorial decisionmaking over time. During the last steps of our process, the “What’s New” home page is designed, with resources chosen, prioritized, and highlighted for publication.

Figure 1 AHRQ PSNet sample annotation

One recurring challenge of our content selection process comes as we try to determine whether a resource is about “safety” (our mandated scope) or “quality” (generally, outside our scope). The distinction between “patient safety” and “health care quality” is by no means clear and is, to some extent, purely academic.7 Although our charge is to focus on patient safety, we do not want to inappropriately exclude quality-focused resources that are also relevant to a safety-oriented audience. For example, a study on the use of information technology (e.g., computerized provider order entry, CPOE) that improved the quality of care delivered to patients with diabetes might be excluded as quality-focused. On the other hand, a similar study demonstrating the role CPOE played in improving beta-blocker use in the perioperative setting might warrant inclusion, given that perioperative beta-blocker use was identified as an important patient safety intervention in an AHRQ technical review (e.g., that defined one aspect of safety practices as cross-cutting).8 The balance here remains challenging and generally defies fixed rules for inclusion and exclusion.

The broader issue involves defining the “market” for patient safety information. Does every black box warning about a medication or device require inclusion? Does an article focused on quality but relating to safety published in a marquee journal trump a safety-specific article in a lower impact journal? These sorts of discussions are resolved through consensus and with an eye toward past user feedback, while keeping in mind our overarching mission: to err on the side of high-quality resources, rather than aiming for an inclusiveness that would likely generate an overwhelming amount of content and a poor user experience.

### Site Attributes

During site development, we identified the chief site attributes as:

- Timely sharing of new information.
- An attractive, usable, and intuitive user interface.
- A customized and searchable set of resources using a taxonomy that offered multiple axes.
- A balance between dynamic content (e.g., literature, meetings, and news) and resource content (e.g., toolkits, conference proceedings, and legislation).

Below, we highlight a few specific features that have been popular with our users and demonstrate the efforts to create a particular user experience on AHRQ PSNet.

### What’s New and AHRQ PSNet Newsletter

We designed an interface on the site to highlight new content—i.e., “What’s New”—and an active way to alert users of the new content: the electronic newsletter. With 20 to 25 carefully chosen resources each week, we still felt the number could potentially overwhelm users on the home page. Instead, we produced a dynamic left side of the home page for “What’s New” and a static right side of the home page for existing content (Figure 2).

Figure 2 AHRQ PSNet home page

In “What’s New,” we select the top 10 to 12 resources each week, organized by resource type (i.e., journal article, newspaper/magazine article, Web resource), and prioritize them based on desired connection between the two sites.

To cue users to explore new content, we provide an opportunity to receive an AHRQ PSNet newsletter that is electronically delivered to subscribers. The email displays the “What’s New” content and allows users to link directly to the individual resources on AHRQ PSNet. We believe this feature is vital for keeping our users easily updated, a primary objective during our site development.

### My PSNet

The “My PSNet” option allows users to view the latest resources available in their self-designated areas of interest. When a new resource matching their specifications is added to AHRQ PSNet, they receive e-mail alerts up to once weekly. The process begins by walking users through a series of check boxes to highlight their interests—e.g., choosing a safety target, an approach to improving safety, a setting of care, a clinical area, a target audience, and an error type. Each of these categories drills down to more specific areas, so each user can customize preferences as broadly as “All Approaches to Improving Safety,” or simply “Teamwork Training.” We believed that by helping users define their areas of interest, matched with our custom developed taxonomy (described below), the user experience would be optimized.

### Classics

Given the volume of content on AHRQ PSNet, we wanted to highlight enduring and influential resources in patient safety—i.e., our “Classics.” After agreeing on an initial list of classics at site launch (with input from our Editorial Board), our editorial team reviews resources every 6 months to designate new “Classics.” Typically, we start with a list of potential resources—all of our selected “key” articles (i.e., those with longer annotation summaries), those highlighted on the “What’s New” home page, and the most frequently viewed and cited resources. The editorial team convenes, chooses a target of approximately 50 new classics per year, and then seeks input from the Editorial Board and Advisory Panel. Once final selections are made, these resources receive the “Classic” designation, increasing its weight and importance in our searching algorithms. We believe this feature provides users, particularly those new to the field, with an easy method to identify landmark resources. A few times a year, we will also designate a particularly noteworthy new resource as an “Instant Classic.”

### Glossary

Building on the success of the AHRQ WebM&M glossary, we reproduced and expanded the glossary on AHRQ PSNet. The glossary terms have grown in number and depth, as many contain links (similar to our annotations) and important references. Given the breadth of the field, a comprehensive glossary helps explain commonly used terms (e.g., “safety culture”) and activities (e.g., root cause analysis) in patient safety. Adding or modifying glossary terms is part of the editorial workflow; new terms are identified or raised by editorial members, often while writing weekly annotations for new resources. AHRQ PSNet and AHRQ WebM&M glossaries are shared, and searching for a phrase on AHRQ PSNet, such as “safety culture,” will provide both the glossary term and the available resources matching the search term.

### Taxonomy

A good user experience on AHRQ PSNet requires sensitive and specific methods for visitors to locate resources. A simple text search (e.g., “culture”) across the site’s resources would be inadequately specific, whereas an unstructured keyword list would quickly become unmanageable due to size and internally redundant. Therefore, we designed a structured categorization of descriptive terms—i.e., a taxonomy—to label resources on AHRQ PSNet. The taxonomy was designed by consensus and iterative review by our editorial team. Taxonomies composed by such expert groups tend to be large; they balance high specificity when describing complex domains at the cost of complexity and decreased usability. We tried to minimize these limitations by carefully restricting the taxonomy to the minimum degree of specificity necessary to support a user experience on a Web site, rather than by attempting to exhaustively describe either the breadth of the field or the distinctions possible within it.

For example, our list of “Medical Complications” is limited to five items—nosocomial infections, pressure ulcers, delirium, venous thrombosis, and falls—rather than an enumeration of every possible medical complication. These five items were selected based on their prominence in the field and the existing literature. While we do sacrifice some specificity in the labeling, we avoid creating the unusable user experience that would result from an attempt to list every possible medical complication.

The taxonomy is organized along 7 descriptive axes: (1) Setting of Care, (2) Target Audience, (3) Clinical Area, (4) Safety Target, (5) Error Types, (6) Approach to Improving Safety, and (7) Resource Origin. Each axis is a hierarchy of terms, ranging from the very general (e.g., Setting of Care > Hospitals) to the very specific (e.g., Safety Target > Medication Safety > Medication Errors > Transcription Errors). Each AHRQ PSNet resource is tagged by professional indexers with zero or more taxonomy terms from each of the seven axes and could be tagged with very specific “leaf” terms, or more general “trunk” terms as appropriate. The tagging drives the site’s “Browse” user experience, where users can conceptually traverse the resource collection along a descriptive axis, or define a targeted search that intersects terms from two or more of the descriptive axes.

In the initial design, the optimum level of specificity was determined subjectively by the editors, with a prejudice toward avoiding an overly complex user experience. As AHRQ PSNet has accumulated content and visitor usage data, we have used statistical methods to identify places in the taxonomy to increase specificity or add new topic areas (e.g., “medication reconciliation” and “red rules” were added after site launch). We anticipate ongoing revisions to the taxonomy, based on statistical analysis, editorial assessment of the trends in the literature, and subjective feedback from the site’s visitors.

## Results

### Site Usage and User Satisfaction

We have monitored the impact of AHRQ PSNet by three mechanisms:

- Site usage—measured by unique visits per month.
- User content selection—measured by analysis of user search behavior and resources accessed.
- User demographics and satisfaction—measured by voluntary survey responses.

As shown in Figure 3, the site has steadily attracted more users since its launch, with an increase from approximately 30,000 visits per month in April 2005 to more than 110,000 in July 2007. Additional data from July 2007 indicate more than 3,600 site visits daily, more than 6,500 subscribers receiving the weekly “What’s New” e-mail newsletter, and more than 3,200 subscribers with established “My PSNet” accounts. At the launch of AHRQ PSNet, the number of visits to it and to AHRQ’s WebM&M were roughly equal. By way of comparison, AHRQ PSNet now has approximately 33 percent more daily visits than AHRQ WebM&M; combined, the two sites are trending toward approximately 2.5 million unique visits per year.

Figure 3 Visits per month to AHRQ PSNet: April 2005 to July 2007

Each time a user accesses the site and views a specific resource, Silverchair’s Web server logs a “hit” for the individual resource item, as well as for the taxonomy terms used to classify that item. For example, if a user viewed an annotation of a journal article on the subject of “medication reconciliation,” it would be recorded as a “hit” for the taxon “Medication Safety.” When a user searches the site, the server also logs the exact search string used. We use monthly summary reports of these data to analyze our user’s content interests. Table 1 shows the most commonly accessed taxons over the past year; they represent the patient safety topics of greatest interest to our users. The diversity of topics, ranging from specific errors and interventions (e.g., “medication errors” and “teamwork training”) to systems and organizational issues (e.g., “nurse staffing ratios” and “culture of safety”) speaks to the varied interests of our readers. Last summer, we conducted a voluntary user survey, gathering data on user satisfaction with the site and user demographic data. Most respondents identified their primary institutional affiliation as a hospital or health care system (60 percent) or academic institution (16 percent). The respondents came from a variety of professions and institutional roles, including nurses, physicians, and quality improvement (QI) and patient safety professionals, indicating that AHRQ PSNet is meeting our goal of providing resources for a diverse array of users (Table 2). Overall, users were very satisfied with the content, features, and ease of use of AHRQ PSNet; 92 percent of respondents stated they would recommend the site to a colleague.

Table 1 Most common search strings and taxonomy areas: July 2006 – July 2007

Top 10 search strings | Top 10 taxonomy areas
“SBAR” (Situation/Background/Assessment/Recommendation) | Nurse staffing ratios
“Falls” | Medication errors/preventable adverse drug events
“Medication reconciliation” | Culture of safety
“Communication” | Look-alike, sound-alike drugs
“Medication errors” | Human factors engineering
“Patient falls” | Patient falls
“CPOE” (computerized provider order entry) | Nosocomial infections
“Patient safety” | Critical care nursing
“Disclosure” | Approach to improving safety
“Culture” | Teamwork training

Table 2 Characteristics of AHRQ PSNet users

Respondent role | Proportion of respondents (%)
Nurse/nurse practitioner | 20
Quality improvement professional | 19
Physician | 14
Risk management professional | 11
Patient safety officer | 9
Administrator/manager of hospital, health plan, or medical group | 6
Pharmacist | 5
Others (e.g., librarians, Federal/State policymakers, students, writers/editors, and researchers) | <5

## Future Directions

In May 2007, responding to the user survey, feedback, and site experiences, we launched an upgraded version of AHRQ PSNet. The improved user interface included easy-to-access navigation on the left and preserved the usability of the site. The upgrade augmented users’ search capabilities using more sophisticated search algorithms. A new “Most Popular” feature highlights the most frequently viewed resources on the site.

Moving forward, we anticipate further upgrades with two specific features in the advanced planning phase: Podcasts and Patient Safety Primers. Podcasts—which are digital media files that can be automatically delivered through subscription feeds—have become a popular method for individuals to stay abreast of their favorite topics by listening at their convenience. Medical journals began offering such features recently, and the interest in developing podcasts for AHRQ WebM&M and AHRQ PSNet seemed natural and was fully supported by AHRQ. Once the technical capacity is built, we will provide podcasts for AHRQ WebM&M and AHRQ PSNet content.

With more than 3,000 content items on AHRQ PSNet, and 20 to 25 new resources added each week, novice users may find it difficult to become familiar with basic patient safety concepts.

For example, searching on “medication reconciliation” (the third most common search term as of fall 2006) yields 42 resources, displayed on three different screens. Since only 39 percent of users in the 2006 AHRQ PSNet user survey identified themselves as patient safety officers or QI/risk management professionals, it is likely that many of our users are relatively new to the field of patient safety and thus, could benefit from editorial guidance in accessing content. Therefore, in the near future we plan to introduce “Patient Safety Primers,” individual pages within AHRQ PSNet written by our editors on important patient safety topics.

The Patient Safety Primers will be organized clearly and will serve four key functions; they will:

1. Provide an introduction to the topic, including its definition, importance, and epidemiology.
2. Direct readers to the content items most relevant to the topic.
3. Improve integration of AHRQ PSNet content with AHRQ WebM&M content.
4. Improve access to both research-oriented and application-oriented content items.

In order to integrate the latest, most relevant content, the Patient Safety Primers will be continuously updated by the editorial team. Introduction of Patient Safety Primers will help move AHRQ PSNet from being a repository and library of patient safety resources toward becoming an even more comprehensive resource for the patient safety community.

## Conclusion

In the past, we have described our first effort at bringing patient safety education to the Internet via AHRQ WebM&M as the “culmination of a bold AHRQ experiment.” AHRQ PSNet represents an extension of that experiment—to become the world’s premier resource for materials related to patient safety—and it appears (according to user response and visit statistics) to have been successful in this regard. In the fields of safety and quality, no comparable products, services, or Web sites provide a one-stop portal that captures important information from diverse sources, organizes the information with careful editorial input, and presents a product with a customized and attractive user interface.

AHRQ PSNet demonstrates the capacity for and value in delivering continuously updated patient safety news and literature to interested stakeholders. We hope these will aid providers, researchers, administrators, and policymakers in preventing medical errors, redesigning safer health care systems, teaching the principles of safety, and collaborating across disciplines and institutions.

## Acknowledgments

We thank Marge Keyes, our AHRQ project officer, for her ongoing and active support; our colleagues at Silverchair for their collaboration and technical assistance; and Kristen Fitzhenry for her invaluable assistance on the project. We also thank all of our dedicated users for their praise and feedback of the site, as their input drives our improvement efforts. Funding for AHRQ PSNet and this article was provided by AHRQ Contract 290-04-0021.

## References

1 Kohn L, Corrigan JM, Donaldson MS, editors. To err is human: Building a safer health system. Washington DC. Committee on Quality of Health Care in America, Institute of Medicine; National Academies Press. 2000.
2 Stelfox HT, Palmisani S, Scurlock C, et al. The “To err is human” report and the patient safety literature. Qual Saf Health Care. 2006;15:174-178. [pmid: 16751466].
3 AHRQ Morbidity and Mortality (M&M) Rounds on the Web. Agency for Healthcare Research and Quality and the University of California, San Francisco Division of Hospital Medicine. AHRQ Contract 290-04-0021. Available at: http://webmm.ahrq.gov/. Accessed April 2, 2008.
4 Wachter RM, Shojania KG, Minichiello T, et al. AHRQ WebM&M – Online medical error reporting and analysis. Advances in patient safety: From research to implementation Vol 4: Programs, tools, and products AHRQ Publication 05-0021-4). Rockville, MD. Agency for Healthcare Research and Quality. 2005. Available at: www.ahrq.gov/downloads/pub/advances/vol4/Wachter.pdf. Accessed April 2, 2008.
5 Clancy CM, Keyes MA. The Agency for Healthcare Research and Quality’s Patient Safety Network. J Patient Saf. 2005;1:124-125.
6 AHRQ Patient Safety Network (PSNet). Agency for Healthcare Research and Quality and the University of California, San Francisco Division of Hospital Medicine. AHRQ Contract 290-04-0021. Available at: http://psnet.ahrq.gov/. Accessed April 2, 2008.
7 Wachter RM, Shojania KG. The patient safety movement will help, not harm, quality. Ann Intern Med. 2004;141:326-327. [pmid: 15313760].
8 Shojania KG, Duncan BW, McDonald KM, et al., editors. Making health care safer: A critical analysis of patient safety practices. Evidence Report/Technology Assessment 43; AHRQ Pub. 01-E058. Rockville, MD. Agency for Healthcare Research and Quality. 2001. Available at: http://www.ahrq.gov/clinic/ptsafety/. Accessed April 2, 2008.