# Systems Redesign

Systems-Based Practice: Improving the Safety and Quality of Patient Care by Recognizing and Improving the Systems in Which We Work

Designing the Built Environment for A Culture and System of Patient Safety – A Conceptual, New Design Process

Implementation of Systems Redesign: Approaches to Spread and Sustain Adoption

Transforming the Morbidity and Mortality Conference into an Instrument for Systemwide Improvement