# Safety Culture and Organizational Issues

The AHRQ Hospital Survey on Patient Safety Culture: A Tool to Plan and Evaluate Patient Safety Programs

Hospital Administrative Staff vs. Nursing Staff Responses to the AHRQ Hospital Survey on Patient Safety Culture

Using the AHRQ Hospital Survey on Patient Safety Culture as an Intervention Tool for Regional Clinical Improvement Collaboratives

Measuring Safety Climate in Primary Care Offices

The PeaceHealth Ambulatory Medication Safety Culture Survey

Views of Emergency Medicine Trainees on Adverse Events and Negligence: Survey Results from an Emergency Medicine Training Program in a Regional Health Care System Following the National Standard of Care

Is There an Association Between Patient Safety Indicators and Hospital Teaching Status?

Organizational Behavior Management in Health Care: Applications for Large-Scale Improvements in Patient Safety

Confidential Performance Feedback and Organizational Capacity Building to Improve Hospital Patient Safety: Results of a Randomized Trial