# Peer Reviewers—Volume 2

The editors thank the following individuals for serving as peer reviewers for manuscripts submitted for publication in Volume 2 of Advances in Patient Safety: New Directions and Alternative Approaches.

Alexander Alonso

William Baine

James Battles

Carrie Brady

Charles Andrew Brown

Denise Burgess

Felicia Cerbone

Katherine Crosson

Charles Darby

Oscar Espinosa

Linda Greenberg

Amy Helwig

Kerm Henriksen

Eileen Hogan

Sandra Isaacson

Brian Jack

Katherine Jones

Harold Kaplan

Ben-Tzion Karsh

Shirley Kellie

Lauren Silver

Joann Sorra

Mark Stanton

Bruce Thomadsen

Eric Thomas

Alene Kennedy

Margaret Keyes

Heidi King

James Levett

David Lewin

Kshitij P. Mistry

Jacqueline Moss

Tim Mulcahy

William Munier

Vinay Nadkarni

Christopher Nemeth

Veronica Nieva

Akira Nishisaki

Pamela Owens

Wilson Pace

Peter Pronovost

Gina Pugliese

Deborah Queenan

John Reiling

Jill Scott-Cawiezell

Patrick Toomey

Robert Wears

Saul Weingart

Chunliu Zhan