# Collaboratives and Patient Involvement

The Patient Safety Education Project: An International Collaboration

Harnessing the Potential of Health Care Collaboratives: Lessons from the Keystone ICU Project

VHA’s National Falls Collaborative and Prevention Programs

Hospital Language Services: Quality Improvement and Performance Measures

Using Patient Complaints to Promote Patient Safety

From Public Testimony to Vehicle for Statewide Action: Experience of the Michigan State Commission on Patient Safety

The Rural Physician Peer Review Model^©^: A Virtual Solution