# Clinical Process Improvement

Resident Sign-Out: A Precarious Exchange of Critical Information in a Fast-Paced World

Documentation of Mandated Discharge Summary Components in Transitions from Acute to Subacute Care

Challenges to Real-Time Decision Support in Health Care

Risk Reduction and Systematic Error Management: Standardization of the Pediatric Chemotherapy Process

Analysis of Patient Safety: Converting Complex Pediatric Chemotherapy Ordering Processes from Paper to Electronic Systems

Promoting Best Practice and Safety Through Preprinted Physician Orders

The Impact of Standardized Order Sets on Quality and Financial Outcomes

Clinical Impact of an Anticoagulation Screening Service at a Pediatric Tertiary Care Facility

Creating Safety in the Testing Process in Primary Care Offices

Role of the External Coach in Advancing Research Translation in Hospital-Based: Performance Improvement

Strategies for Improving Patient Safety in Small Rural Hospitals