# Taxonomies and Measurement

Development of a Comprehensive Medical Error Ontology

Mapping a Large Patient Safety Database to the 2005 Patient Safety Event Taxonomy

A System to Describe and Reduce Medical Errors in Primary Care

Beyond Nursing Quality Measurement: The Nation’s First Regional Nursing Virtual Dashboard

Using ICD-9-CM Codes in Hospital Claims Data to Detect Adverse Events in Patient Safety Surveillance

Adaptation of AHRQ Patient Safety Indicators for Use in ICD-10 Administrative Data by an International Consortium

Racial Disparities in Patient Safety Indicator (PSI) Rates in the Veterans Health Administration