# Risk Assessment

Risk-Based Patient Safety Metrics

Leveraging Existing Assessments of Risk Now (LEARN) Safety Analysis: A Method for Extending Patient Safety Learning

A Model of Care Delivery to Reduce Falls in a Major Cancer Center

Using a Computerized Fall Risk Assessment Process to Tailor Interventions in Acute Care

Home Health Care Patients and Safety Hazards in the Home: Preliminary Findings