# Reporting Systems

Improving the Value of Patient Safety Reporting Systems

The Association Between Pharmacist Support and Voluntary Reporting of Medication Errors: An Analysis of MEDMARX^®^ Data

Proactive Postmarketing Surveillance: Overview and Lessons Learned from Medication Safety Research in the Veterans Health Administration

Medical Product Safety Network (MedSun) Collaborates with Medical Product Users to Create Specialty Subnetworks

Physician-Reported Adverse Events and Medical Errors in Obstetrics and Gynecology

26,000 Close Call Reports: Lessons from the University of Texas Close Call Reporting System

Using an Anonymous Web-Based Incident Reporting Tool to Embed the Principles of a High-Reliability Organization

Voluntary Adverse Event Reporting in Rural Hospitals

Improving Error Reporting in Ambulatory Pediatrics with a Team Approach

Relationship Between Patient Harm and Reported Medical Errors in Primary Care: A Report from the ASIPS Collaborative

Structure and Features of a Care Enhancement Model Implementing the Patient Safety and Quality Improvement Act