# Peer Reviewers—Volume 1

The editors thank the following individuals for serving as peer reviewers for manuscripts submitted for publication in Volume 1 of Advances in Patient Safety: New Directions and Alternative Approaches.

Kay Anderson

Carrie Brady

Jeff Brady

Pascale Carayon

Judy Consalvo

Jay Crowley

Elizabeth Dayton

W. Sherman Edwards

Marybeth Farquhar

Janet Firshein

Linda Greenberg

Ruth Ann Hadley

Brenda Harding

Amy Helwig

Kerm Henriksen

Alene Kennedy

Mark Keroack

Margaret Keyes

Christopher Landrigan

Kate Lapane

Judy Sangl

Jill Scott-Cawiezell

Marjorie Shofer

Erik Stalhandske

Ron Stock

Jeffrey Taekman

Peter Layde

Kathryn Leonhardt

Russell Mardon

John Messenger

Gregg Meyer

Ernest Moy

Tim Mulcahy

William Munier

Dorothy Naylor

Christopher Nemeth

Akira Nishisaki

Patrick O’Connor

Caitlin Oppenheimer

Marcy Opstal

Pamela Owens

Wilson Pace

Cynthia Palmer

Deborah Queenan

Geoffrey Rake

Karen Rudzinski

Bruce Thomadsen

Saul Weingart

Donna Woods

Chunliu Zhan

Brenda Zierler