# Looking Forward, Benefiting from the Past

Envisioning Patient Safety in the Year 2025: Eight Perspectives

What Exactly Is Patient Safety?