# Challenges and Lessons Learned

Patient Safety Learning Pilot: Narratives from the Frontlines

A Visual Computer Interface Concept for Making Error Reporting Useful at the Point of Care

Christiana Care Health System: Safety Mentor Program

News Media and Health Care Providers at the Crossroads of Medical Adverse Events