# Cause Analysis

The New York Model: Root Cause Analysis Driving Patient Safety Initiative to Ensure Correct Surgical and Invasive Procedures

Department of Veterans Affairs Emergency Airway Management Initiative

Using Root Cause Analysis to Reduce Falls in Rural Health Care Facilities

Common Cause Analysis: Focus on Institutional Change