# Leveraging Existing Assessments of Risk Now (LEARN) Safety Analysis: A Method for Extending Patient Safety Learning

## Abstract

Prospective risk assessments are being conducted at health care institutions across the country in response to the Joint Commission requirement. However, an opportunity is being missed to combine these risk assessments to identify generic risks and risk contributors across institutions. The U.S. Department of Energy (DOE) applies a successful methodology, known as “risk binning,” to analyze a group of risk assessments to identify generic risks and risk contributors. Establishing high-priority targets and identifying effective interventions for health care are essential to improve patient safety. This article describes how the Leveraging Existing Assessments of Risk Now (LEARN) Safety Analysis method can be used to analyze a group of risk assessments through the application of “risk binning” methodology to existing risk assessments from multiple institutions.

## Background

Risk assessments, such as failure modes and effects analysis (FMEA), have been shown to be effective for identifying, assessing, and addressing risks in many life-critical industries that must function with high reliability, including medicine.1, 2 The process of conducting a thorough FMEA in medicine is time and resource intensive, yet the results of these detailed assessments are rarely shared.

The U.S. Department of Energy (DOE) has developed a successful standardized methodology using “risk binning,” which enables the analysis of a group of risk assessments across institutions to identify generic risks and risk contributors from processes and systems.3 In this article, we use a group of risk assessments to illustrate the application of this methodology in medicine.

Although prospective risk assessments are being conducted at health care institutions across the country in response to the Joint Commission’s requirement, an important opportunity is being missed—i.e., using these risk assessments to identify generic risks and risk contributors to improve the understanding of similar processes across institutions. By adapting methods from other high-risk industries, risk assessments from multiple institutions can be analyzed to improve our understanding of the significant risks and risk contributors of health care processes across institutions. This approach could result in medicine achieving greater success in reducing errors and risks similar to the success achieved by the field of energy.

This article presents a detailed example of the application of the adapted DOE methods to leverage existing knowledge via an analysis of a group of existing health care risk assessments (e.g., FMEAs), much like a meta-analysis. These methods can be useful in health care contexts to advance the knowledge of potential risks in the systems and processes in health care. The identification of generic risks and risk contributors can then be used to shape the design of safety interventions and controls to improve patient safety.

### DOE Safety Analysis Methods

DOE uses a “Safety Analysis” process to develop controls (safety interventions) for non-reactor nuclear facilities. Briefly, this Safety Analysis method includes four basic steps that involve several substeps:

1. Identifying hazards by the participating institutions prior to the grouping of risk assessments.
2. Performing hazard evaluations using failure events from existing risk assessments.
3. Selecting candidate accidents by:
  a. “Binning” failure events into accident categories and according to other relevant criteria.
  b. Selecting representative cases (emblematic case scenarios representing a particular contour of risk) to further evaluate and identify risks and risk contributors.
4. Identifying safety controls or interventions to reduce risk.

### Adapting the Method to Health Care

Terminology, contexts, and processes in health care differ from other high-risk industries, and these differences must be accommodated for effective application of the Leveraging Existing Assessments of Risk Now (LEARN) Safety Analysis method to health care. The following sections describe the initial modifications of the process and criteria necessary for this method to be applied effectively to health care.

To be clear, this LEARN Safety Analysis method is not intended to provide an epidemiology of types of events. The LEARN Safety Analysis method is more akin to a meta-analysis of risk assessment data to glean and combine the results of many studies. These types of data qualitatively analyze existing risks inherent in medical care processes and cannot adequately generate rates of events.

FMEA prospective risk assessments are intended to specify the particular way that processes fail. Risk assessments are conducted on processes thought to need improvement. The results of these risk assessments are failure modes—i.e., how the system fails. The risks related to these fail points, common to a number of institutions’ risk assessments (generic risks), are identified as generic risks. The contributors to these risks that are common to a number of institutions’ risk assessments are generic risk contributors and are identified and described. The processes and criteria described here will be further modified iteratively through use.

The DOE method has been adapted from evidence-based criteria found in the available patient safety literature related to performance-shaping factors and child-specific risk factors by applying different accident category/event types appropriate for health care. The extent of an increase or decrease in the frequency of risk and resulting consequence(s) are considered based on these criteria.

### Step 1: Identify Hazards

The hazards are identified in the risk assessments that are subsequently grouped.

### Step 2: Hazard Evaluations

This step is also completed during the risk assessments (i.e., FMEA, root cause analysis [RCA], probabilistic risk assessment [PRA]). The following questions are typically asked (Table 5):

Table 5 Risk bin categories

Consequence level | Beyond extremely unlikely | Extremely unlikely | Unlikely | Anticipated
High | III | II | I | I
Moderate | IV | III | II | I
Low | IV | IV | III | III

- “What can go wrong?” — to identify fail points.
- “How likely is it?” — to identify frequency.
- “What are the consequences?” — to identify harm.

Table 1 provides an example the types of information received in the risk assessments for analysis.4

Table 1 Example FMECA worksheet for correct blood transfusion

Step ID | Step | Success criteria | Failure mode | Cause | Category | | | Comment | Risk
Step ID | Step | Success criteria | Failure mode | Cause | Freq. | Cons. | Safe-guard | Comment | Risk
5.10 | Document results in computer or downtime log | Correct crossmatch | Enter incorrect information into computer or into log | Human error interruptions | F1 | CP4 | S5 | Computer or log entry triggers blood issuance. | High
5.11 | Print or handwrite crossmatch results on blood unit tag in lab | Document correct patient and blood type | Incorrect or illegible handwritten label | Human error | F2 | CP1 | S2 | Make handwritten labels only during computer downtime (<1% of time). If info is wrong, the Fenwal armband on patient will catch the error. | Low
5.12 | Attach printed (or handwritten) blood unit tag to donor blood and Fenwal # sticker | Correct tag on correct unit | Put wrong tag on unit | Processing multiple specimens at one time | F2 | CP3 | S2 | Later, the Red Cross label will be checked against the unit tag. | Med

FMECA = failure modes, effects, and criticality analysis

### Step 3: Selecting a Candidate Accident

Selecting the candidate accident requires multiple substeps. The fail points are categorized according to the type of event, using the categories, performance-shaping factors, and patient characteristics (e.g., child-specific risk factors) described below and underlying thematic similarities (i.e. handoffs, verification of task completion). This set of categories, developed through a review of patient safety events, is appropriate for health care. The categories are effective for designating medical care processes in both hospital-based and ambulatory medical care.5

Step 3.1: Accident categories/event types (Table 2).

Table 2 Accident categories/event types

1. Preventive medicine (immunization and preventive screening).; 2. Diagnostics (medical history and physical examination, diagnostic testing, reading, recording, and interpreting results).; 3. Treatment; - Medications, blood products, fluid, diet (ordering, transcribing, dispensing, and administration).; - Surgical and nonsurgical procedures (preparation, performance of the procedure, and post-procedural care).; - Appointment scheduling, referral, and followup communications.; - Other medical treatments (psychiatric, social services, and discharge planning).; 4. Patient monitoring (monitoring of patient status).; 5. Patient communication (communication, education, consent, and confidentiality for preventive care diagnostics, medications, non-surgical procedures and surgical care, post-surgical care, and other medical treatments).; 6. Patient identification.; 7. Equipment-related (equipment malfunction, equipment availability, and use of equipment).; 8. Administrative (medical records and other clinically significant administrative processes).

Step 3.2: Criteria – Performance-shaping factors. The fail points are categorized by performance-shaping factors (Table 3). The performance-shaping factors follow the framework presented by Charles Vincent as “factors that influence clinical practice.”6

Table 3 Performance-shaping factors in health care

1. Institutional context (economic and regulatory context).; 2. Organizational and management factors (financial resources, policy standards and goals, and safety culture priorities).; 3. Work environment (staffing levels and skills mix; workload and shift patterns; design, availability, and maintenance of equipment; and administrative and managerial support).; 4. Team factors (verbal communication, written communication, supervision and help seeking, and team structure).; 5. Individual staff factors (knowledge and skill, motivation, physical and mental health).; 6. Task factors (task design and clarity of structure and availability and use of protocols).

Step 3.3: Criteria – Child-specific risk factors. There is growing evidence that the epidemiology of errors and patient safety risk differs in pediatrics from that of adult medical care.7, 8, 9 Specific characteristics of children—“child-specific risk factors”—have been shown to lead to patient safety risk.5, 9, 10 Nevertheless, the literature establishing high-priority targets and effective interventions for pediatric patient safety is relatively limited.11, 12 Further study is needed to improve the safety of children’s medical care. Most inpatient and emergency medical care for children is delivered in institutions that primarily treat adults and may have only a small pediatric service.

These institutions are unlikely to have a pediatric emergency medicine physician on staff, and they may lack basic pediatric equipment and skills.12, 13 They are also unlikely to conduct proactive risk assessments that focus on children’s medical care and might not have the requisite personnel or expertise to conduct such an analysis. Research on pediatric patient safety has established “child-specific risk factors” (Table 4) and has demonstrated how these factors contribute to patient safety risk. Studies are emerging that demonstrate the need for pediatric customization of safety interventions to prevent increases in morbidity and mortality when safety interventions are implemented.14, 15 The application of these factors can add one step to a risk assessment to specify particular risks to child patients from the results of a general risk assessment.

Table 4 Child-specific risk factor categories

Physical characteristics; - Small size, weight, and morphology; - Varied physical characteristics including significant variation in size, weight, and morphology
Physiological development; - Developing physiologic systems; - Varied signs and symptoms; - The impact of growth
Cognitive-social-emotional development; - Developing nature of understanding; - Communication capability; - Behavioral regulation
Minor/legal status; - Parental responsibility for medical management; - Decisionmaking and consent; - Confidentiality; - Supervision

For example, the context of pediatric medication ordering requires the consideration of two child-specific factors: (1) physical characteristics (e.g., variable size) and (2) physiologic development (e.g., limited or variable physiologic development). Medication dosage must be customized based on weight and physiologic state (e.g., kidney function). These additional steps in the medication ordering process can result in increased risk of error. What might seem to be a relatively minor misplacement of a decimal point in calculating the medication dose can result in a 10-fold error, often with serious consequences for pediatric patients. Additional criteria could be applied for other subpopulations of patients. Figure 1 shows further classification based on child-specific factors.

Figure 1 Additional analysis using child-specific risk factors.

In applying the method to medicine, a representative case of this type of failure would be further assessed to identify the potential impact of the performance-shaping factors of emergency medicine. For example, the influence of performance-shaping factors, such as frequent interruptions and time pressures on medication ordering, would be assessed to estimate the frequency of risk and determine the risk bin.

Through the application of these child-specific risk factor criteria, an additional analysis could be conducted to further specify particular risks specific to children’s health care to inform safety improvement of the subpopulation of pediatric patients. Additional criteria could be applied for other subpopulation of patients. Figure 1 show further classification based on child-specific factors.

Step 3A. Risk-binning analysis protocol to identify significant risks. The categories of frequency and consequence of each fail point are used in combination to identify the significant (relatively higher) risks through a process called “risk binning.” Table 5 illustrates a matrix for the application of these sets of criteria. In this schema, risks assessed in Risk Bin IV are low to moderate consequence and extremely unlikely to beyond extremely unlikely. The highest risks with the highest consequence are in Risk Bin I, the next highest in Risk Bin II, and so forth. Failure events in Risk Bins I and II become the focus for targeted attention.

Identified failure events in the assessed processes are reviewed for frequency of occurrence, the resulting consequence, and the safeguard effectiveness (Table 6) based on the results of the risk assessment. They are then modified iteratively through the review of a dedicated risk assessment team, according to the child-specific risk factors and “medicine performance-shaping factors,” to evaluate the potential need for adjustment to increase or decrease the assessment of frequency, and consequence. The combination of frequency and consequence categories are used to calculate a level of patient risk that is defined as High, Medium, or Low. Safeguard effectiveness is dropped out of this analysis as safeguards usually refer to institution specific safety features. A separate analysis of safeguards can generate particularly effective safeguards that may warrant broader adoption.

Table 6 Frequency and consequence of failure mode categories and safeguard effectiveness categories

Category | Frequency | Description
F1 | Remote | Possible, no known data (happens once in 10 years)
F2 | Uncommon | Documented but infrequent (happens once a year)
F3 | Occasional | Documented and frequent (happens once a month)
F4 | Very frequent | Documented, occurs routinely (happens more than once a month)
Category | Consequence | Description
CP0 | None | No impact on the chance of failure mode
CP1 | Little | Little impact on the chance of failure mode
CP2 | Some | Some impact on the chance of failure mode
CP3 | Significant | Significant impact on the chance of failure mode
CP4 | Certain | Almost certain chance of failure mode
Category | Safeguard Type | Description
S1 | Multiple checks | Hospital procedure has a formal built-in check and other safeguards
S2 | Formal check | Hospital procedure includes a formal built-in check
S3 | Standard practice | Standard practice includes a check
S4 | Noticeable | Worker notices and responds
S5 | Nondetectable | The failure is not detectable

Step 3B. Selection of representative cases. In the adapted LEARN Safety Analysis methodology, after “risk binning” the failures, representative cases are selected for each represented accident category that falls into Risk Bins I or II, the highest risk categories. Representative cases are those that are emblematic of the risk scenarios identified. For example, the selection of representative cases in the nuclear industry is based primarily on grouping failure events by causes, physical characteristics, and the potential for severity of consequences for particular relevant phenomena, such as fire. In this study, these groups are called “failure categories.” Representative cases are then selected from the failure categories.

Typically, in the DOE Safety Analysis process for important topics—such as facility handling or processing of nuclear material—the types of representative cases would include such cases as fires, leaks, and load drops. Representative cases provide an embedded context of risk that enables exploration of the complexity of the context.

Selection of representative cases for this adapted methodology uses the child-specific factors (e.g., medication ordering, accident category, variable size and weight, and immature physiology of a young child), the performance-shaping factors (e.g., distractions and noise, verbal communication of orders, and lack of staff with pediatric training), and the underlying thematic failure similarities as categories. The cases themselves determine the need for refinement. This categorization results in generic themes of risks and specific contributors to these risks and the selection of potential risk-reducing interventions.

### Step 4: Identify Risk Contributors

Examination of representative cases identifies generic risks and risk contributors. Through iterative analysis, these risks and risk contributors should be listed and grouped to consolidate and direct attention toward high-impact contexts of risk. Risk assessments can be reviewed to examine specific risks found, based on specific organizational or process features called “institutional artifacts,” risks or safeguards due to the specific method, process, or a specific organizational structure present. Potential examples of institutional artifacts we may encounter include computerized physician order entry (CPOE) or inclusion of a pediatric pharmacist in rounds on a particular service.

### Step 5: Design of Safety Interventions and Controls

In the analysis of representative cases, the hierarchy of safety improvement strategies can be applied toward development of potential safety interventions aimed at mitigating the generic risks and risk contributors. We present here a modified hierarchy of interventions based initially on that developed by Vaida and The Institute for Safe Medication Practices.16 The design of potential safety interventions can be informed by the error preventing or mitigating strength of the intervention. The modified hierarchy of interventions includes:

1. Forcing functions.
2. Automation, computerization, and technology.
3. Standardization and protocols.
4. Staffing organization.
5. Policies, rules, and expectations.
6. Checklists & double-checks.
7. Risk assessment and communication errors.
8. Education and information.
9. Personal initiative – vigilance.

It is important to remember that the resulting safety interventions require further testing before they can contribute new or additional fail-points. This LEARN Safety Analysis method can then become another method for prospective assessment of implementation of safety interventions across institutions.

## Conclusion

The LEARN Safety Analysis method can provide several methods for assessment: (1) a catalogue of risks across institutions, (2) identification of underlying generic risks, (3) an additional step that can supplement and customize the risk results for special populations and specialized medical care contexts, and (4) an analysis of the relative safety or risk of specific institutional artifacts.

This method may have particular advantages for health care organizations that include multiple institutions. The LEARN Safety Analysis method can be applied to risk assessment information grouped across the institutions to inform broader organizational patient safety needs and goals.

Hospital associations and patient safety organizations could bring together institutions interested in improving the safety of a specific context of medicine and “drilling down” to specific risks and risk contributors that exist across institutions, as well as underlying generic risks that may exist across a variety of safety topics. The findings from such applications could then be used to develop safety interventions that could then be tested and supported through “Learning Collaboratives.”

Finally, this method can be used by oversight or regulatory organizations to provide an overview of generic risks and risk contributors and to serve as a basis for moving the entire U.S. health care system to higher and safer standards of care.

## References

1 Joint Commission Resources. Failure modes and effects analysis in healthcare. Oakbrook Terrace, IL. Joint Commission. 2005.
2 Engineers study design, hospital cuts falls 50%. Healthcare Risk Manage. 2006. 1 Aug. Available at: www.accessmylibrary.com/coms2/summary_0286-17375523_ITM. Accessed March 18, 2008.
3 Preparation guide for U.S. Department of Energy nonreactor nuclear facility documented safety analyses, change notice No. 2; DOE-STD-3009-94 Washington, DC US Department of EnergyAvailable at: hss.energy.gov/NuclearSafety/techstds/standard/std3009/doe-std-3009-94_cn3_3-30-06.pdf Accessed March 18, 2008
4 Coles G, Young J. Use of failure modes effects and criticality analyses to improve impatient safety. Safety Analysis and Risk Assessment Division of the ASME International Congress and Exposition. 2002. Nov 17–22. New Orleans, LA.
5 Woods DM, Thomas EJ, Holl JL, et al. Adverse events and preventable adverse events in children. Pediatrics. 2005;115:155-160. [pmid: 15629994].
6 Vincent C. Framework for analyzing risk and safety in clinical medicine. Br Med J. 1998;316:1154-1157. [pmid: 9552960].
7 Miller MR, Elixhauser A, Zhan C. Patient safety events during pediatric hospitalization. Pediatrics. 2003;11:1358-1366. [pmid: 12777553].
8 Woods DM, Bhatia MM, Ogata E, et al. Child-specific risk factors and patient safety. J Patient Saf. 2005;1:17-22.
9 Slonim AD, LaFleur BJ, Ahmed W, et al. Hospital reported medical errors in children. Pediatrics. 2003;111:617-621. [pmid: 12612245].
10 Mohr JJ, Lannon CM, Thoma KA, et al. Learning from errors in ambulatory pediatrics (LEAP). Advances in patient safety: From research to implementation. Research findings. AHRQ Pub. 05-0021-1. Rockville, MD. Agency for Healthcare Quality and Research. 2005;1. Available at: http://www.ahrq.gov/downloads/pub/advances/vol1/Mohr.pdf. Accessed March 18, 2008.
11 Miller MR, Pronovost PJ, Burstin HR. Pediatric patient safety in the ambulatory setting. Ambul Pediatr. 2004;4:47-54. [pmid: 14731091].
12 Warden GL, Sundwall DN, editors. Institute of Medicine report – Emergency care for children: Growing pains. Washington, DC. National Academies Press. 2006.
13 Gaushe-Hill M, Lewis R, Schmitz C. Pediatric preparedness of U.S. emergency departments: A 2003 survey. Pediatrics. 2007;120:1229-1237. [pmid: 18055671].
14 Han YY, Carcillo JA, Venkataraman ST, et al. Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. 2005;116:1506-1512. [pmid: 16322178].
15 Woods DM, Mohr JJ, Mehra M, et al. Anatomy of a patient safety event. A taxonomy for pediatric patient safety. Qual Safe Health Care. 2005;14:422-427.
16 Institute for Safe Medication Practices. Medication error prevention “toolbox.” Medication safety alert. June 2. 1999. Available at: www.ismp.org/msaarticles/toolbox.html. Accessed May 30, 2008.