# Using Probabilistic Risk Assessment to Model Medication System Failures in Long-term Care Facilities

## Abstract

Objectives: State agencies and Oregon's long-term care providers cosponsored this developmental study to explore the creation of two statewide medication system risk models using sociotechnical probabilistic risk assessment (ST-PRA). This paper summarizes the methodology involved in this ongoing project. Methods: A convenience sample of l8 facilities participated. Seven multi-disciplinary modeling teams used process mapping, control system mapping, modified failure modes and effects analysis, and ST-PRA to create consolidated ST-PRA models, one for nursing facilities and one for community-based care (CBC)—i.e., residential care/assisted living—facilities. Discussion: The models provide contextual maps of the errors and behaviors that lead to medication delivery system failures, including unanticipated risks associated with regulatory practices and common deviations from policies and procedures. Policymakers, regulators, and managers can identify, prioritize, and prospectively model risk reduction interventions using ST-PRA. Conclusion: ST-PRA models can identify systemic and behavioral elements that increase or reduce the risk of wrong-drug, wrong-dose, omitted-dose or -drug, and wrong-patient medication administration errors in nursing and CBC facilities.

## Introduction

Most medication errors studies have been done in the acute care setting, whereas comparatively few studies have been done in long-term care (LTC) institutions. ^1,^ ^2^ Information about the medication delivery systems in LTC facilities is fragmented, largely drawn from retrospective incident analyses or regulatory surveys, and lacks the detail necessary to design systems interventions to reduce the risk of serious errors occurring statewide. The Agency for Healthcare Research and Quality (AHRQ), through its Risk Assessment Challenge Grant to Oregon's public health agency and the Oregon Health Care Association (OHCA), is extending the application of modern, prospective risk-modeling methods to the identification, prioritization, and mitigation of patient safety risk in the LTC setting.

OHCA (Oregon's association of long-term care providers), State regulators, and public health leaders involved in the design of this study are seeking to determine whether sociotechnical probabilistic risk assessment (ST-PRA) ^3^ can be used to identify common systemic and behavioral elements that increase or reduce the risk of serious errors. A second goal is to determine whether these models can be used to design statewide risk-reduction programs for nursing and community-based care (CBC) long-term care facilities. Four classes of patient events (wrong-drug, wrong-dose, omitted-dose/drug, and wrong-patient medication errors) were modeled because they occur frequently and/or have potentially serious clinical consequences. ^1,^ ^4^ This research explores the feasibility of consolidating input from multiple institutions to derive two Oregon “master risk models,” one model for nursing facilities and another for CBC (residential care facilities with more than 20 beds and assisted living facilities). Residential care facilities with fewer than 20 beds are excluded from the sample because they are often quite different in scope, structure, and operation compared to the facilities in this sample.

Until recently, health care did not have the tools necessary to prospectively analyze or concurrently compare causal mechanisms for different types of adverse events. This situation is changing as health care begins to adopt safety engineering methods from the nuclear power and aviation industries. ^5^ – ^7^ Introduced by accreditors to reduce the risk of future errors, root cause analysis ^8^ and failure modes and effects analysis (FMEA) ^9^ are primarily being practiced in the hospital environment. ^10,^ ^11^ These techniques represent the most basic type of causal or risk analysis. A more advanced technique that models multiple combinations of events leading to a single outcome, sociotechnical probabilistic risk assessment, has been successfully used to develop prospective risk models for hospital medication delivery systems. ^3^ In this study, ST-PRA is used to consolidate input from 10 nursing and 8 CBC facilities to create risk models that describe potential failure combinations resulting from processing prescriber orders; transcription activities; medication, inventory, and storage activities; pharmacy dispensing; and medication administration practices in these facilities. The models focus on processes within the direct control of the facilities, so that potential failure combinations resulting from pharmacy internal dispensing practices are not modeled. However, pharmacy dispensing errors—internal or external—that enter the facility are captured in the models.

State and LTC leaders anticipate that these risk models—because they display and quantify the complex relationships between system elements, organizational culture, behavioral norms, regulatory requirements, and undesirable outcomes—will guide development of realistic medication safety policies, identify high-yield interventions, and substantially accelerate statewide risk-reduction efforts. The models will be validated using a random, stratified sample of Oregon nursing and CBC facilities in a later stage of this research. This paper presents a high-level description of the model building phase of this research. The final report will include a detailed discussion of ST-PRA methodological issues and results of the validation effort. Readers desiring more detailed information on ST-PRA are referred to Marx and Slonim. ^3^

## Methods

### Design

The Oregon Long-term Care Medication Risk Modeling project is a developmental study; it is the first health care study using ST-PRA to create medication risk models for multiple LTC facilities.

### Sample

A convenience sample of 6 LTC chains and l8 facilities participated in the study. One organization operated a single large campus and participated in both the nursing and CBC modeling. There were 10 nursing facilities from 4 nursing chains, ranging in size from 88 to 214 licensed beds. Three CBC chains provided eight facilities: five assisted living and three residential care facilities. The size of the assisted living facilities (ALFs) ranged from 60 to 87 licensed beds, and the three residential care facilities ranged in size from 64 to 122 beds. The modeling teams were composed of trained ST-PRA facilitators, 1 or 2 research staff, and medication staff (nurses, certified medication aides, and caregivers) recruited from the 18 facilities. Over the course of 3 months, four chain-specific nursing facility teams and three CBC teams met to build medication risk models using the ST-PRA process.

### Overview of ST-PRA Modeling

The central tool of ST-PRA is the risk tree, also known as a fault tree. An ST-PRA risk tree starts with a top-level event, which is the undesirable outcome (e.g., a wrong dose delivered to a patient). Risk modeling teams then identify the failures that link together, leading to the top-level event. The risk tree in Figure 1 illustrates the interrelationships between human errors, cultural or behavioral norms, systems, and equipment failures that together may lead to a top-level event.

Figure 1 Example of risk or fault tree—dose transcribing error

This risk tree illustrates an initiating error (order taker writes down the wrong dose) combining with a read-back of the order that fails to catch the error, and three other capture opportunities that do not catch the initiating error. In the process of building the ST-PRA models, the modeling teams used Relex software (Version 7.6; Relex Software Corp.; Greensburg, PA) to identify 50–500 different combinations of failures leading to a particular top-level event risk being analyzed. What follows is a description of the major steps of ST-PRA as applied in the Oregon project.

### Major steps in the Oregon risk assessment process

1 Organizing risk modeling teams. Facility managers nominated staff based on each person's knowledge of medication systems and their ability to communicate candidly about the processes and behaviors that could lead to system failures within their facilities. A total of 16 nurses and certified medication assistants (CMAs) participated in the nursing facility modeling groups. A total of 14 nurses and caregivers participated in the CBC modeling groups. Staff members from the same chain were grouped together, and each chain-specific group met four times for approximately 3 hours. Groups typically included one or two staff from two or three different facilities. Pharmacists and physicians associated with chains participated in separate focus groups, reviewing the preliminary models and providing feedback about their accuracy and completeness.
2 Build initial process maps. Beginning with an undesirable outcome or top-level event, each modeling team developed preliminary process maps that represented medication delivery processes under the direct control of the facility (processing of prescriber orders, transcription, receipt/storage of delivered drugs, pharmacy dispensing errors, medication administration) for each of the four classes of patient events being studied. Process maps helped establish the scope of the model by putting bounds on the processes and types of medications to be analyzed by the teams.
3 Build control systems maps. Control system mapping is a tool for identifying both active and passive controls in the process being modeled. Active controls are features of the system that are in place to specifically help manage the risks of the undesirable outcome under analysis. For example, a unit dose or blister-pack cards are active controls that reduce the chance of wrong-dose errors. Passive controls are those features of the system that help control the specific risk under analysis, but that exist in the system for some purpose other than controlling the risk being modeled (e.g., the shape and color of pills). The purpose of identifying these controls is to be able to evaluate them through ST-PRA modeling.
4 Identify process and control system failure modes. In the Oregon model, system components are the physician, pharmacist, nurse, records clerk, medication aide, and resident. While we rarely refer to humans as system components, they are components in the ST-PRA risk tree. Once the process and control system maps were complete, the modeling teams used a modified FMEA analysis to identify individual failures (errors, at-risk behaviors, systems, and equipment failures) that could lead to the undesirable outcome under analysis. The FMEA provided the source data for building the initial risk trees.
  Table 1 Examples of summary failure modes and effects analyses
  Process | Failure mode | Downstream controls | Failure effect
  In-room patient identification | Nurse enters wrong room | Visual identification of patient | Medication delivered to wrong patient (note: ST-PRA will model failures of downstream controls that might capture nurse entering wrong room before medication reaches the wrong patient)
  | | Arm band check
  | | Verbal name check
  | | Verbal discussion of medication with patient
  Physician ordering | Medication order written in wrong chart | Nurse review of order | Medication administered to wrong patient (note: ST-PRA will model failures of downstream controls that might capture the physician error before reaching the patient)
  | | Pharmacy review of order
  | | Verbal discussion of medication with patient
5 Build initial risk trees. With failure modes in hand, the risk modeling teams began building the initial risk trees, creating “branches” or “splits” whenever they identified a significant variation, for example, whether medication staff pull their blister-packed drug cards by taking them from bins presorted by administration time, or use the medication administration record (MAR) to pull individual cards sorted by patient name or room number. Risk trees went through multiple iterations until the modeling groups were satisfied that they have captured the most important elements of the process.
6 Collect quantitative denominator data. Denominator data for creating rates for the events that are represented in the risk trees were collected from participating nursing and CBC facilities. The research team analyzed data from random, stratified samples of de-identified MARs to establish nursing and CBC per-order and per-dose denominators for error rates. Standardized rates for the average number of prescriber orders and oral doses of medications delivered per staff per year were developed from these MAR analyses. These rates were used during the modeling meetings; for example, if a nurse said she saw a particular error (such as an omitted dose) twice a week, the team used the denominator data to turn the time frequency estimates into an estimate of errors per dose. Throughout the model building, the teams continued collecting data to support the analysis.
7 Estimate human error, at-risk behavior, control systems, and equipment failure rates. Once the risk models were well developed, the modeling team members began to identify and estimate data—based upon their experience, the experience of others where applicable, published rates, and human-reliability expert input—for rates of control systems failures, at-risk behaviors, errors per medication order, and errors per oral medication dose. During the process-mapping and risk tree-building stages, modeling teams found many variations in process. These included how medication bins or drawers were organized (by shift, by time of administration, or in alphabetical order by either patient names or drug names), how medications were delivered (pop/pass/sign versus sign/pop/pass), as well as the use of medication carts versus preparation in a medication room. The modeling teams were required to explore the relative risks of each variation—some being assessed directly, other variations requiring risk tree modeling to determine the relative merits of one variation versus another.
  The teams also had to develop rates for at-risk behaviors, such as failure to check the MAR when administering medications. This is a commonplace at-risk behavior not easily identified in postevent investigations, particularly in terms of estimating a normative rate for a particular institution. Nurses and caregivers spend long shifts getting to know the patients, their diagnoses, and their medications. Despite policies and procedures that require checking the MAR during medication administration, medication staff admit that in practice, for a variety of reasons, they fail to universally accomplish this safety check. ^12^
  The teams noted that even if pharmacies or medication aides entered the time on blister-packed oral medications to operationally fulfill the “five rights” (right patient, right drug, right dose, right time, right route), skipping the MAR check could lead to a wrong-drug, wrong-dose or omitted-dose error if the MAR contained new orders to add, change, or discontinue drugs. The group discussed rates of failure to check the MAR based on different ratios: 1 in 100 doses, 5 in 100 doses, or 50 in 100 doses. The models were calculated based on the team's rate estimates. The focus group then reviewed the probability estimates and either agreed with what the model identified as the risks, or went through the estimation process again until they reached a consensus. Through this repetitive process, the interdisciplinary team arrived at an estimate for the local cultural norm for checking the MAR. Experience indicates that these team estimates are more accurate than rates derived from event data, and are often more accurate than rates predicted by senior management within the facility. ^13,^ ^14^
8 Run the quantitative model and “cut set” reports. After the rate estimates were put into the model, the software calculated intermediate- (gate) and top-level event probabilities (i.e., for wrong drug, dose, resident, or omission). PRA software will generally produce a report listing the probabilities of each unique combination of failures, a “cut set,” that could produce the top-level event. The software ranks the combinations of failures according to their probabilities, allowing the modeling teams to focus on those combinations of errors that have the highest probability of producing the medication error being modeled.
9 Compare the model against data and group expectations. Team members continued iterative development of the model until the model represented the best available representation of the risk. Once completed, the chain-specific models were shared with chain management, pharmacy representatives, and nursing facility medical directors to collect their observations and input.
10 Consolidating risk models. This project was designed first to build chain-specific models, and then merge the models into consolidated models of nursing and CBC facilities. Very early in the project, the research team found that medication processes and rates described by each team were similar and decided instead to develop only one model for each facility type, nursing and CBC. Across chains and facilities, the critical elements of taking prescriber orders, transcribing them, ordering and receiving drugs from pharmacies, storing, and administering medications were similar, with occasionally important variations requiring new branches in the risk trees.

Modeling medication delivery systems risks in multiple facilities mirrors the challenges of building single-hospital models, where input from many different units or departments must be accommodated during the model-building process. Also, the scale and politics are different; for example, direct competitors had to agree to share their models during consolidation. However, the processes for building these models are essentially the same as would be followed for individual institutions. Single institutions represent far fewer logistical problems; modeling is usually completed within a few days rather than weeks. The processes followed within the modeling groups, however, reflected the typical ST-PRA group experience.

Variations identified by the groups required judgment calls by the modeling team (group members and consultants) to assure a reasonable scope for the project. Many low-risk failure paths and many inconsequential variations were not built out in the model, but were modeled at a high level. Practice differences by shift or individuals were common within single facilities, as well as procedural differences between facilities within the same chain. Policies and procedures varied by chain, for example, whether a chain initially purchased a 3- to 14-day supply of medications to bridge the gap created by delayed preauthorizations by insurers. Group members believed there was less likelihood of “borrowing” medications to assure continuous therapy if this policy was in place. This variation is included in the models because it could raise or lower the cumulative risk of an error occurring. If an event was identified and might be worthy of future study, it was included in the risk trees as an undeveloped event. An example of this is the variety exhibited in borrowing practices when drugs are not available. Hundreds of variations in medication delivery practice were seen across the sites, but most had little or no impact on serious medication errors that reach residents. Variation and subsequent judgment calls regarding what should be modeled are common in aviation and nuclear power PRAs, as well. ^15,^ ^16^

Probably the most difficult task associated with creating these models was keeping all the modeling group and quantitative data organized and accurately recorded. In every group meeting, at least one and often two research team members recorded data. With seven groups running more or less simultaneously, the research team had to devise methods to record and synthesize large amounts of information over relatively short periods of time by using spreadsheets, the risk analysis software, and copious note taking.

## Discussion

The scope of this paper does not permit exploration of the underlying methodologies brought together in ST-PRA modeling techniques. ST-PRA model building requires knowledge of human factors, human reliability, probability theory, group dynamics ^3^ —as well as, in this particular study, a dose of public policy. In the best of circumstances, probability assessment models are subject to missed failure paths, mischaracterized dependencies between errors, and misestimated failure rates. Furthermore, model design is driven by the need to keep the models to a manageable size, while addressing the danger that process and procedural variations that may lead to risk could be left out. ^13,^ ^15,^ ^16^ Notwithstanding these inherent limitations of the probabilistic risk assessment methodology, we believe that ST-PRA offers four advantages over current risk management methodologies.

1 ST-PRA provides a structure and process for gathering sometimes highly sensitive information about policy, procedure, and/or behavioral deviations not otherwise available. (See the discussion in “Modeling the real versus the ideal medication delivery system.”)
2 The models provide contextual maps of the errors and behaviors that lead to system failures so that policymakers, regulators, and managers can identify, prioritize, and prospectively model risk-reduction interventions using ST-PRA. ^3^ (See the discussion in “Understanding the context of errors.”)
3 Models are dynamic; they are designed to evolve as fresh data from new studies, patient safety reporting systems, or facility incident reporting systems are used to refine probability estimates for different elements in the models. ^3^
4 Policymakers and regulators are able to appreciate the unanticipated consequences of particular enforcement actions, such as increased medication-borrowing behavior to avoid citations for “drug not available” or the time pressures introduced by interpretations of the Federal “2-hour rule,” ^17^ governing the time within which a drug is administered to a resident. (See the discussion in “Role of risk models and regulation.”)

### Modeling the real versus the ideal medication delivery system

Given the prospective nature of ST-PRA, modeling teams are willing to describe and discuss common deviations from policies and procedures (P&Ps) that they would otherwise not divulge, for fear of criticism or punishment. ^12^ For example, rates of noncompliance for checking the MAR before giving medications are not generally reported in the literature, nor are there any descriptions of the behaviors that lead up to borrowing medications from one patient's supply to sustain treatment for another patient. These practices are generally forbidden in P&Ps, but this study found that they occur with some frequency to cope with circumstances that are often outside the staff's control. Given that the ST-PRA modeling teams were making assessments of future risk, they were much more open about what really happens in the administration of medications.

Modeling teams explained that most borrowing occurs when a clinically important drug (such as an antibiotic, anticonvulsive, anticoagulant, cardiovascular, or analgesic) is not immediately available in the form or dose needed by a particular patient. Concerned about the impact on the resident of missing one or more doses of these drugs, a staff member borrows the drugs to assure therapeutic continuity. Borrowing also occurs when insurer preauthorization policies delay acquisition of clinically important drugs. Sometimes borrowing occurs to avoid surveyor citations for “drug not available” entries in the MAR. Borrowing results because emergency boxes are not typically stocked with every dose and form of a drug; preauthorization approval can take 2 weeks or more; someone can forget to order a refill; or the pharmacy is unable to deliver the drug on time. The model estimates the risks associated with these types of practices. Managers and policymakers can decide if the size of the risk requires action on their part and, if so, have some clues about where to intervene.

### Understanding the context of errors

In addition to providing access to largely unobtainable behavioral data, risk modeling provides context unavailable in single-event investigations, such as root-cause analysis. Single-event analyses cannot capture the range of combinations of elements that might operate to produce the same outcome—they can only describe what occurred in the event under study. The example above, which describes borrowing practices, illustrates that there are multiple reasons why a particular behavior or event occurs. ST-PRA offers the advantage of modeling several variations of systems and their human components, including behaviors associated with specific work processes.

During this study, the modeling teams were able to visualize the “system” of medication delivery through defining the combinations of failures that lead to delivery of incorrect medications to a resident. They learned the value of redundant control systems and capture opportunities from the model. For example, repeated checking of transcribed orders from one month's MAR to the next substantially reduced the probability of errors involving incorrectly transcribed doses or drugs reaching the resident. Modeling teams and managers can use the models to see the interrelationships between component reliability and system reliability—an interrelationship that, if ignored, can lead to blaming individuals for failures outside of their control. Too often, when adverse events occur, health care professionals lack the time and/or resources to thoroughly understand the elements and risk factors that led up to the incident, resulting in sometimes unfocused, punitive, or piecemeal solutions. ^18^ Health care institutions tend to focus only on the breach—the error that contributed to the patient event—and ignore the important contributions of the system and component failures that preceded the individual's lapse. ^19^ This is both an unfair and unrealistic approach to error management, particularly if the error arose from systems failures outside of the control of the individual.

The Oregon risk models force us to see serious medication errors in the context of the systems that produce them, leading to a better understanding of both systemic and human component safety risks. Having these models provides Oregon policy, public health, and LTC leaders with a common mental model to establish priorities for planning and evaluating alternative statewide medication risk-reduction strategies. ^20^ At the facility level, managers can use the rankings of relative risks for the modeled errors to determine where to concentrate limited resources for maximum risk reduction.

### Role of risk models and regulation

Troyan Brennan ^21^ has argued that regulation cannot improve quality if it depends primarily on licensing and disciplinary actions to achieve what he calls “culling,” or removing defective performers. Brennan offers five recommendations for improving quality through regulation. ST-PRA risk models can be used to achieve or inform each of Brennan's recommendations:

- Help regulators integrate new knowledge into public policy
- Support the development of shared regulatory/provider aims
- Encourage provider self-improvement
- Support innovation to improve quality
- Improve outcomes (risk) measurements

Unfortunately, space does not permit an in-depth discussion of each of these recommendations; however, the following example helps to illustrate the unique contributions of ST-PRA risk models.

Oregon's public health and regulatory leaders, in partnership with the LTC provider community, intend to use the models to develop shared goals or aims for quality and risk reduction in the State. These models provide State regulators and policymakers with a view of risk that can inform both future legislation and current enforcement practices. For example, regulators were unaware that the so called “2-hour rule” ^17^ —currently interpreted by Oregon surveyors as meaning that all medications (including vitamins and nutritional supplements) must be administered in the “window” of 1 hour before or after the time specified in the prescriber's orders—would play a prominent role in the risk modeling. This rule encourages undesirable, at-risk behavioral norms or short cuts, as medication staff delivering large volumes of medications at certain times of the day become pressed for time. Regulators and providers now have an opportunity to discuss these findings objectively and to evaluate how to reach their shared goal of timely medication administration to achieve therapeutic efficacy. Through the model, Oregon regulators and providers can begin a dialogue to analyze the alternative, associated risks using an evidence-based approach to narrow the scope of the rule by asking: Which risks are increased? Which are decreased?

### ST-PRA as a tool for State-level change

Even though it has been used for decades to make very important policy and operational decisions in other high-risk industries, probabilistic risk modeling is a new tool in health care. ^16^ As noted earlier, while the ST-PRA methodology has limitations, it is uniquely suited to prospective risk assessment of combinations of events leading up to the top-level event or undesirable outcome. A skilled and knowledgeable leader or team is required to guide a modeling group through the ST-PRA process, gaining group member trust and encouraging the candor necessary to discuss deviations from policy that are often ignored or underestimated by outsiders. Model-building teams require enough time to carry out the development of accurate and complete risk trees, which are critical to the success of the ST-PRA. In this particular study, the underlying common medication processes (ordering, transcribing, receipt/storage, and administration) were similar across facilities, and, while important variations were identified, they did not prevent consolidation of each chain's models into one “master model” for nursing facilities and one for CBC facilities. How interfacility and interchain variances are addressed during model building requires good process and control-system modeling, judgment, and PRA skills on the part of the team leaders. Consolidated models would have been large and relatively unmanageable if each facility had unique processes in place.

This type of State-level assessment requires trust between all parties, a significant commitment of resources, protection of this very sensitive data to maintain confidentiality, consideration of potential policy or legal consequences to participants, and an agreement that the model(s) will be used to improve quality rather than to punish the provider community. The public-private partnering demonstrated in this study requires trust and cooperation between the State agency and provider leadership. ^22^

Finally, through this research, the OHCA and State of Oregon partnership will have a representative model of the active controls LTC organizations can put into place to manage the risks of medication error. The control-system model that accompanies the ST-PRA will provide an overall mapping of the strategies in place to manage medication risk. A new piece of these controls is the ST-PRA itself, which provides guidance to system managers on the risks inherent in medication delivery systems and the relative contribution of each active control to reducing the risk of medication error. Each medication adverse event investigated by State agencies or participating facility will become a learning opportunity to inform the risk model, by either validating the model or adding risk elements not discovered in the initial ST-PRA development. The result of this research is a “living risk management system” that can and should be used by system managers to manage the risks of medication error. ^3^

## Conclusions

This paper provides an overview of ST-PRA modeling and how it has been used in Oregon to create multifacility probabilistic risk models describing the systems, controls, and behavioral elements that can increase or decrease the risks of serious medication errors or omitted doses in nursing and CBC facilities. These findings are important because most errors are invisible to providers and patients, leaving them with the impression that errors are either trivial or infrequent. ^23^ The modeling process reveals important systems relationships, unintended consequences of regulatory enforcement, and important risk-reduction innovations that merit dissemination. These models can guide LTC leaders and policymakers toward common goals and can accelerate risk-reduction efforts.

ST-PRA models establish the behavioral and systems context that either increases or decreases the probability of errors occurring. This research tool estimates, often for the first time, the frequency of important policy, procedural, or behavioral deviations that are usually missed in discussing the source of medication errors—for example, the practice of borrowing drugs from one resident's supply to give to another resident whose drugs are not yet available. The models provide important insights and describe causal relationships missing from global measures sometimes used in health care, e.g., studies associating higher or lower medication error rates to nurse staffing ratios. ^24^ The ST-PRA models and the interventions based on them have the potential to become the foundation of an active public-private, statewide medication risk management program focused on sustained risk reduction and learning from errors. ^25^

If the Oregon models are successfully validated, the State will begin to move from the current incremental, institution-by-institution change mode to one that employs comprehensive risk models to guide coordinated private and public sector practice improvement efforts, substantially accelerating risk reduction across a broad segment of the provider community. Through the risk modeling process, State and provider community leaders can see which system attributes and which component failures (errors, behaviors, or equipment failures) have the most impact on common medication errors and focus their resources on improvements likely to bring the most benefit to Oregon's citizens.

## Acknowledgments

This project is supported by grant # UC1HSO14259 from the Agency for Healthcare Research and Quality.

Our deepest appreciation goes to the management and staff of the six long-term care chains whose generous sharing of information and resources made this study possible. We thank Thomas W. Brundage, statistician with the Oregon Department of Human Services (DHS) for his advice and assistance. We thank Lynn Hanson and Pamela Ruona, Oregon DHS/Seniors and People with Disabilities, and Linda Kirschbaum, Oregon Health Care Association (OHCA) for their contributions to the modeling teams. We thank Grant Higginson, Oregon State Public Health Officer, Cynthia Hannum, DHS/Seniors and People with Disabilities, and Jim Bishop, OHCA Executive Director, for their leadership and willingness to make this study happen. We also thank Megan Hornby, DHS/Seniors and People with Disabilities, for her counsel and encouragement, and Joel Young, DHS/Health Service/Health Systems Planning, for his vision and skilled advocacy for the project. A special thanks to Dawne Marx for her skillful edits and suggestions.

## References

1 Gurwitz JH, Field TS, Avorn J, et al. Incidence and preventability of adverse drug events in nursing homes. Am J Med. 2000;109:87-94. [pmid: 10967148].
2 Allan EL, Barker KN. Fundamentals of medication error research. Am J Hosp Pharm. 1990;47:555-71. [pmid: 2180287].
3 Marx D, Slonim A. Assessing patient safety risk before the injury occurs: an introduction to socio-technical probabilistic risk assessment in healthcare. Qual Saf Health Care. 2003;12(Suppl II):ii33-ii38. [pmid: 14645893].
4 Barker KN, Flynn EA, Pepper GA, et al. Medication errors observed in 36 health care facilities. Arch Intern Med. 2002;162:1897-90. [pmid: 12196090].
5 Helmreich RL. On error management: lessons from aviation. BMJ. 2000;320:781-5. [pmid: 10720367]. [pmcid: 1117774].
6 Van der Schaaf TW. Medical applications of industrial safety science. Qual Saf Health Care. 2002;11:205-6. [pmid: 12486976].
7 Spencer FC. Human error in hospitals and industrial accidents: current concepts. J Am Coll Surg. 2000;191:410-8. [pmid: 11030247].
8 Joint Commission on Accreditation of Healthcare Organizations. Sentinel events: evaluating cause and planning improvement. Oakbrook Terrace, IL: JCAHO; 1998.
9 American Hospital Association, Health Research and Educational Trust, and the Institute for Safe Medication Practices. Pathways to medication safety: looking collectively at risk. Chicago; 2002.
10 Pape TM. Applying airline safety practices to medication administration. Medsurg Nsng. 2003;12:77-93.
11 Fletcher CE. Failure mode and effects analysis. JONA. 1997;27(12):19-26.
12 Gladstone J. Drug administration errors: a study into the factors underlying the occurrence and reporting of drug errors in a district general hospital. J Adv Nurs. Oct. 1995;22(4):628-37. [pmid: 8708180].
13 Martz HF, Picard RR. On comparing PRA results with operating experience. Reliab Eng and Syst Safety. 1998;59:187-99.
14 Brown A, Haugene B. Assessing the impact of management and organizational factors on the risk of tanker grounding. Proceedings of the 8th International Offshore and Polar Engineering Conference; 1998 May 24–29; Quebec, Canada. Cupertino, CA: International Society of Offshore and Polar Engineers; 1998. pp. 469–76.
15 Macwan A, Mosleh A. A methodology for modeling operator error in probabilistic risk assessment. Reliability Eng and Syst Safety. 1994;45:139-57.
16 Linnerooth-Bayer J, Wahlstrom B. Applications of probabilistic risk assessment: the selection of appropriate tools. Risk Analysis. 1991;11:239-48. [pmid: 1876723].
17 Centers for Medicare and Medicaid Services. Survey procedures for long-term care facilities. Part II: Guidance to surveyors—long-term care facilities, FTag333 [43CFR Section 483.25(m)]; Baltimore, MD: 1999.
18 Cook RI, Woods DD. Operating at the sharp end: the complexity of human error. In: Bogner MS, editor. Human error in medicine. Hillsdale, NJ: Lawrence Erlbaum; 1994. pp.255–310.
19 Leape L, Bates DW, Cullen DJ, et al. Systems analysis of adverse drug events. JAMA. 1995;274:35-43. [pmid: 7791256].
20 Aspden P, Corrigan JM, Wolcott SM, et al. Comprehensive patient safety programs in health care settings. In: Patient safety: achieving a new standard of care. A report of the Institute of Medicine. Washington, DC: National Academy Press; 2004.
21 Brennan TA. The role of regulation in quality. Milbank Qtrly. 1998;76:709-32.
22 Comden SC, Rosenthal J. Statewide patient safety coalitions: a status report. Portland, ME: National Academy for State Health Policy; 2002.
23 Berwick DM. Errors today and errors tomorrow. N Engl J Med. 2003;348:2570-2. [pmid: 12815144].
24 Blegen MA, Vaughn T. A multisite study of nurse staffing and patient occurrences. Nurs Econ. Jul-Aug. 1998;16(4):196-203. [pmid: 9748985].
25 Yourstone SA, Smith HL. Managing system errors and failures in health care organizations: suggestions for practice and research. Health Care Mgmt Rev. 2002;27:50-61.