# Peer Reviewers—Volume 2

The editors wish to thank the following individuals for acting as peer reviewers for manuscripts submitted for publication in Volume 2 of Advances in Patient Safety: From Research to Implementation:

James Battles

Carmen Birk

Mark Bruley

Katherine Crosson

Kimberly Galt

Sheldon Greenfield

Louis Halamek

Michael Harrison

Kerm Henriksen

Lee Hilborne

Bentzi Karsh

Mark Keroack

Margaret Keyes

Beth Kohsin

Christine Kovner

Peter Layde

Mark Linzer

Eric Marks

Debbie McKay

Dwight McNeill

Marlene Miller

Bridget Olson

Ginette Pepper

Geoffrey Rake

Douglas Roblin

Judy Sangl

Lucy Savitz

Stephen Small

Meghan Snide

Daniel Stryer

David Studdert

Christie Teigland

Jonathan Wilwerding