# Safety Culture and Organizational Issues

Creating a Culture of Patient Safety through Innovative Hospital Design

From Science to Service: A Framework for the Transfer of Patient Safety Research into Practice

Making a Case for Organizational Change in Patient Safety Initiatives

Organizational Climate of Staff Working Conditions and Safety—An Integrative Model

A Conceptual Model for Disclosure of Medical Errors