# Cognition, Systems, and Risk

Diagnostic Failure: A Cognitive and Affective Approach

Diagnosing Diagnosis Errors: Lessons from a Multi-institutional Collaborative Project

Cognitive Artifacts' Implications for Health Care Information Technology: Revealing How Practitioners Create and Share Their Understanding of Daily Work

Clinical Inertia and Outpatient Medical Errors

A Conceptual Framework for Studying the Safety of Transitions in Emergency Care

Evaluating and Predicting Patient Safety for Medical Devices with Integral Information Technology

Work System Analysis: The Key to Understanding Health Care Systems

Observing Nurse Interaction with Infusion Pump Technologies

Usability Testing and the Relation of Clinical Information Systems to Patient Safety

Re-engineering the Hospital Discharge: An Example of a Multifaceted Process Evaluation

Using Probabilistic Risk Assessment to Model Medication System Failures in Long-term Care Facilities

A Model-based Approach to Prioritizing Medical Safety Practices