# Medication Safety

Translating Patient Safety Research into Clinical Practice

Development of a Computerized Adverse Drug Event (ADE) Monitor in the Outpatient Setting

Preparing for Ambulatory Computerized Prescriber Order Entry by Evaluating Preimplementation Medication Errors

Language, Literacy, and Communication Regarding Medication in an Anticoagulation Clinic: Are Pictures Better Than Words?

Methodological Challenges in Describing Medication Dosing Errors in Children

Development of a Multipurpose Dataset to Evaluate Potential Medication Errors in Ambulatory Settings