# Surveillance

Fundamentals of Medicare Patient Safety Surveillance: Intent, Relevance, and Transparency

Medical Injury Identification Using Hospital Discharge Data

Mixed Methods Analysis of Medical Error Event Reports: A Report from the ASIPS Collaborative

Development and Implementation of The University of Texas Close Call Reporting System