# Measurement and Taxonomies

Applying Patient Safety Indicators (PSIs) Across Health Care Systems: Achieving Data Comparability

Validation of AHRQ's Patient Safety Indicator for Accidental Puncture or Laceration

Readmissions for Selected Infections Due to Medical Care: Expanding the Definition of a Patient Safety Indicator

Patient Safety Research in Medical Group Practices: Measurement and Data Challenges

Developing a Taxonomy for Coding Ambulatory Medical Errors: A Report from the ASIPS Collaborative

Taxonomic Guidance for Remedial Actions

The Brighton Collaboration: Creating a Global Standard for Case Definitions (and Guidelines) for Adverse Events Following Immunization