# Peer Reviewers—Volume 1

The editors wish to thank the following individuals for acting as peer reviewers for manuscripts submitted for publication in Volume 1 of Advances in Patient Safety: From Research to Implementation:

David Baker

Les Becker

Mark Callahan

Christine Crofton

Denise Dougherty

Timothy Dresselhaus

Stanley Edinger

Sheri Eisert

Bradley Evanoff

Mike FitzMaurice

Andrea Hassol

Kerm Henriksen

Lee Hilborne

Robert Kane

Bentzi Karsh

Margaret Keyes

John Kralewski

Peter Layde

David Magid

Robert Mentzer, Jr.

Glenn Merchant

Marlene Miller

Ron Nosek

Patrick O'Connor

Wilson Pace

Mary Pittman

Richard Platt

Kimberly Rask

Douglas Roblin

Jules Rosen

Judy Sangl

Suzanne Streagle

Nicholas Warren

Robert Wears

Joel Weissman

Jay Wolfson

Chunliu Zhan