# Policy and Medical Expenditures

Regulation of Health Policy: Patient Safety and the States

What Happens After a Patient Safety Event? Medical Expenditures and Outcomes in Medicare

Financial and Demographic Influences on Medicare Patient Safety Events