# Ambulatory and Rural

Learning from Errors in Ambulatory Pediatrics

Identification, Classification, and Frequency of Medical Errors in Outpatient Diabetes Care

From Here to There: Lessons from an Integrative Patient Safety Project in Rural Health Care Settings

Comparing Patient Safety in Rural Hospitals by Bed Count