# Technology

Making Information Technology a Team Player in Safety: The Case of Infusion Devices

Post-fielding Surveillance of a Guideline-based Decision Support System

The Role of Patient Safety in the Device Purchasing Process