# Surveillance

Detection of Inpatient Health Care Associated Injuries: Comparing Two ICD-9-CM Code Classifications

Surveillance of Surgery-related Adverse Events in Missouri Using ICD-9-CM Codes

Developing a Veterans Health Administration (VHA) Serious Injury Surveillance System that Includes Adverse Event Hospitalizations

A Study of Adverse Occurrences and Major Functional Impairment Following Surgery

Measuring Safety: A New Perspective on Outcomes of a Long-term Intensive Case Management Program

The Impact of a Patient Safety Program on Medical Error Reporting