# Medication Safety

Best Practices in Medication Safety: Areas for Improvement in the Primary Care Physician's Office

Quantitative and Qualitative Analysis of Medication Errors: The New York Experience

Reporting of Adverse Drug Events: Examination of a Hospital Incident Reporting System

Prescribing Safety in Ambulatory Care: Physician Perspectives

Impact of Pharmacy-led Dyslipidemia Interventions on Medication Safety and Therapeutic Failure in Patients

Outpatient Benzodiazepine Prescribing, Adverse Events, and Costs

Preventing Medication Errors in Ambulatory Care: The Importance of Establishing Regimen Concordance

A Patient Safety Program & Research Evaluation of U.S. Navy Pharmacy Refill Clinics