# The Clinical Environment

Can We Talk? Priorities for Patient Care Differed Among Health Care Providers

Implementing Safety Cultures in Medicine: What We Learn by Watching Physicians

An Analysis of Nurses' Cognitive Work: A New Perspective for Understanding Medical Errors

Do Transient Working Conditions Trigger Medical Errors?

Organizational Climate, Stress, and Error in Primary Care: The MEMO Study

Seamless Care: Safe Patient Transitions from Hospital to Home