# References

1 National Center for Chronic Disease Prevention and Health Promotion. The Power of Prevention; Chronic Disease … The Public Health Challenge of the 21st Century. 2009. Accessed July 10, 2024. https://stacks.cdc.gov/view/cdc/5509
2 Rasmussen SR, Thomsen JL, Kilsmark J, . Preventive health screenings and health consultations in primary care increase life expectancy without increasing costs. Scand J Public Health. 2007;35(4):365–372. doi:10.1080/14034940701219642 17786799
3 Borsky AE, Zhan C, Miller T, Ngo-Metzger Q. Few Americans receive all high-priority, appropriate clinical preventive services. Health Aff. 2018;37(6):925–928. doi:10.1377/hlthaff.2017.1248
4 Li Y, Pan A, Wang DD, . Impact of healthy lifestyle factors on life expectancies in the US population. Circulation. 2018;138(4):345–355. doi:10.1161/CIRCULATIONAHA.117.032047 29712712
5 Ngo-Metzger Q, Moyer V, Grossman D, . Conflicts of interest in clinical guidelines: update of U.S. Preventive Services Task Force policies and procedures. Am J Prev Med. 2018;54(1S1):S70–S80. doi:10.1016/j.amepre.2017.06.034 29254528
6 Epling JW, Borsky AE, Gerteis J. Improvements to the US Preventive Services Task Force recommendation statement. JAMA. 2019;322(12):1143–1144. doi:10.1001/jama.2019.11311 31550039
7 Bibbins-Domingo K, Whitlock E, Wolff T, . Developing recommendations for evidence-based clinical preventive services for diverse populations: methods of the U.S. Preventive Services Task Force. Ann Intern Med. 2017;166(8):565–571. doi:10.7326/M16-2656 28265649
8 Fragala MS, Shiffman D, Birse CE. Population health screenings for the prevention of chronic disease progression. Am J Manag Care. 2019;25(11):548–553.31747233
9 Fu MR. Real-time detection and management of chronic illnesses. Mhealth. 2021;7:1. doi:10.21037/mhealth-2020-2 33634184
10 Viswanathan M, Rains C, Hart LC, . Primary Care Interventions to Prevent Child Maltreatment: An Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 235. AHRQ Publication No. 23-05307-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2024.
11 World Health Organization. Child Maltreatment. 2022. Accessed July 10, 2024. https://www.who.int/news-room/fact-sheets/detail/child-maltreatment
12 Administration on Children, Youth and Families, Administration for Children and Families. Child Maltreatment 2021. 2023. Accessed July 10, 2024. https://www.acf.hhs.gov/sites/default/files/documents/cb/cm2021.pdf
13 Lewis BA, Freebairn L, Tag J, . Adolescent outcomes of children with early speech sound disorders with and without language impairment. Am J Speech Lang Pathol. 2015;24(2):150–163. doi:10.1044/2014_AJSLP-14-0075 25569242
14 Catts HW, Bridges MS, Little TD, Tomblin JB. Reading achievement growth in children with language impairments. J Speech Lang Hear Res. 2008;51(6):1569–1579. doi:10.1044/1092-4388(2008/07-0259) 18695010
15 Conti-Ramsden G, St Clair MC, Pickles A, Durkin K. Developmental trajectories of verbal and nonverbal skills in individuals with a history of specific language impairment: from childhood to adolescence. J Speech Lang Hear Res. 2012;55(6):1716–1735. doi:10.1044/1092-4388(2012/10-0182) 22562827
16 Dubois P, St-Pierre MC, Desmarais C, Guay F. Young adults with developmental language disorder: a systematic review of education, employment, and independent living outcomes. J Speech Lang Hear Res. 2020;63(11):3786–3800. doi:10.1044/2020_JSLHR-20-00127 33022192
17 O’Connor E, Evans C, Henninger M, Redmond N, Senger C, Thomas R. Interventions for High Body Mass Index in Children and Adolescents: An Evidence Update for the U.S. Preventive Services Task Force. Evidence Synthesis No. 237. AHRQ Publication No. 23-05310-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2024.
18 Stierman B, Afflux J, Carroll MD, . National Health and Nutrition Examination Survey 2017–March 2020 Prepandemic Data Files—Development of Files and Prevalence Estimates for Selected Health Outcomes. Hyattsville, MD: National Center for Health Statistics; 2021.
19 Centers for Disease Control and Prevention. BMI Percentile Calculator for Child and Teen. Accessed July 10, 2024. https://www.cdc.gov/bmi/child-teen-calculator/widget.html (https://www.cdc.gov/healthyweight/bmi/calculator.html)
20 Chou R, Bougatsos C, Griffin J, . Screening, Referral, Behavioral Counseling, and Preventive Interventions for Oral Health in Children and Adolescents Ages 5 to 17 Years: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 232. AHRQ Publication No. 23-05304-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2023.
21 National Institutes of Health. Oral Health in America: Advances and Challenges. 2021. Accessed July 10, 2024. https://www.nidcr.nih.gov/sites/default/files/2021-12/Oral-Health-in-America-Advances-and-Challenges.pdf
22 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. 2000. Accessed July 10, 2024. https://www.nidcr.nih.gov/sites/default/files/2017-10/hck1ocv.%40www.surgeon.fullrpt.pdf
23 Institute of Medicine. Advancing Oral Health in America. Washington, DC: National Academies Press; 2011.
24 Agency for Healthcare Research and Quality. 2022 National Healthcare Quality and Disparities Report. 2022. Accessed July 10, 2024. https://www.ahrq.gov/research/findings/nhqrdr/nhqdr22/index.html
25 Dye BA, Mitnik GL, Iafolla TJ, Vargas CM. Trends in dental caries in children and adolescents according to poverty status in the United States from 1999 through 2004 and from 2011 through 2014. J Am Dent Assoc. 2017;148(8):550–565.e7. doi:10.1016/j.adaj.2017.04.013 28619207
26 Roberts NL, Mountjoy-Venning WC, Anjomshoa M, . Global, regional, and national incidence, prevalence, and years lived with disability for 354 diseases and injuries for 195 countries and territories, 1990-2017: a systematic analysis for the Global Burden of Disease Study. Lancet. 2018;392(10159):1789–1858. doi:10.1016/S0140-6736(19)31047-5 30496104
27 Cantor A, Holmes R, Bougatsos C, Atchison C, DeLoughery T, Chou R. Screening and Supplementation for Iron Deficiency and Iron Deficiency Anemia in Pregnancy: A Systematic Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 239. AHRQ Publication No. 24-05313-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2024.
28 Mei Z, Cogswell ME, Looker AC, . Assessment of iron status in US pregnant women from the National Health and Nutrition Examination Survey (NHANES), 1999–2006. Am J Clin Nutr. 2011;93(6):1312–1320. doi:10.3945/ajcn.110.007195 21430118
29 Surveillance Epidemiology and End Results Program. Cancer Stat Facts: Female Breast Cancer. 2023. Accessed July 10, 2024. https://seer.cancer.gov/statfacts/html/breast.html
30 Surveillance Epidemiology and End Results Program. Breast: SEER 5-Year Age-Adjusted Incidence Rates, 2016-2020, by Race/Ethnicity, Female, All Ages, All Stages. National Cancer Institute; 2024.
31 Surveillance Epidemiology and End Results Program. SEER*Stat Database: Incidence—SEER Research Limited-Field Data With Delay-Adjustment, 22 Registries, Malignant Only, November 2021 Submission (2000-2019)—Linked To County Attributes—Time Dependent (1990-2019) Income/Rurality, 1969-2020 Counties. National Cancer Institute; 2022.
32 Henderson JT, Webber, EM, Weyrich M, Miller M, Melnikow J. Screening for Breast Cancer: A Comparative Effectiveness Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 231. AHRQ Publication No. 23-05303-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; 2024.
33 Surveillance Epidemiology and End Results Program. Breast: SEER 5-Year Age-Adjusted Incidence Rates, 2016-2020, By Subtype, Female, All Races/Ethnicities, All Ages, All Stages. National Cancer Institute; 2023.
34 Surveillance Epidemiology and End Results Program. Breast: SEER 5-Year Age-Adjusted Mortality Rates, 2016-2020, By Race/Ethnicity. National Cancer Institute; 2023.
35 Centers for Disease Control and Prevention. Web-based Injury Statistics Query and Reporting System (WISQARS). Accessed July 10, 2024. http://www.cdc.gov/injury/wisqars
36 Moreland B, Kakara R, Henry A. Trends in nonfatal falls and fall-related injuries among adults aged 65 years—United States, 2012–2018. MMWR Morb Mortal Wkly Rep. 2020;69(27):875–881. doi:10.15585/mmwr.mm6927a5 32644982
37 Kkara R, Bergen G, Burns E, Stevens M. Nonfatal and fatal falls among adults aged 65years—United States, 2020–2021. MMWR Morb Mortal Wkly Rep. 2023;72(35):938–943. doi:10.15585/mmwr.mm7235a1 37651272