# THE USPSTF IN 2024 AND OTHER HIGHLIGHTS

“Together, the Community Preventive Services Task Force and the USPSTF provide evidence-based recommendations on clinical and community preventive services. The research gaps identified by the USPSTF inform where future research is needed that can help people stay healthy. We join the USPSTF in its call for additional research for people across the lifespan and hope that by addressing these gaps, we can continue to work together to provide the best preventive healthcare to people of all ages and in all communities.”

Alison Evans Cuellar, PhD

Chair

Community Preventive Services Task Force

Over the past year, the Task Force members continued working on a full portfolio of topics. The current USPSTF library includes 90 preventive service recommendation statements, with 142 specific recommendation grades. Many recommendation statements include multiple recommendation grades for different populations. In fiscal year 2024 (October 1, 2023, to September 30, 2024), the Task Force accomplished the following:

- Received 28 nominations for new topics and 25 nominations to reconsider or update existing topics
- Posted 8 draft research plans for public comment
- Posted 6 draft recommendation statements and 6 draft evidence reports for public comment
- Published 8 final recommendation statements with 4 recommendation grades in medical journals; posted 8 final evidence reports

For a listing of all final USPSTF recommendations released since the last report, see Appendix D.

## Partner Engagement to Develop and Disseminate Recommendations

The USPSTF continued to work with its partner organizations to enhance the accuracy and relevance of its recommendations, disseminate the work of the USPSTF, and facilitate implementation of the Task Force recommendations into practice. USPSTF partner organizations include Federal agencies that are stakeholders in the process and Dissemination and Implementation Partners that represent primary care clinicians, consumers, and other stakeholders involved in the delivery of primary care.

Partners are a powerful vehicle for ensuring that the nation’s primary care workforce remains up to date on USPSTF recommendations. The complete list of partners is available in Appendices B and C.

## Efforts to Reduce Disparities in Healthcare

The Task Force has worked to improve the health of people nationwide since it was established in 1984. Over the years, the Task Force methods have evolved to include a health equity framework. This health equity framework is used to help the Task Force more consistently approach the recommendation development for all populations that experience inequities in morbidity or mortality from disease related to age, sex, race and ethnicity, sexual orientation, gender, geographical location, and social determinants of health. This approach supports the Task Force’s efforts to promote the highest level of health and well-being for everyone, in all communities.

The health equity framework includes a checklist of key items addressing how health equity issues can be approached at each phase of the USPSTF recommendation development process:

- Topic nomination, selection, and prioritization
- Development of research plan
- Evidence review
- Evidence deliberation
- Development of recommendation statement
- Recommendation dissemination

The Task Force continues to advance its approach to its recommendation development process aimed at reducing the effects of social injustices in healthcare and ultimately helping better equip clinicians with the evidence-based guidance they need to promote health and prevent disease across the lifespan, in all communities.

## Dissemination Impact of USPSTF Recommendations

The USPSTF engages in several activities to disseminate its recommendations to increase their uptake. During the past fiscal year (October 1, 2023, to September 30, 2024), clinicians, patients, and other stakeholders viewed the USPSTF recommendations via the USPSTF website, the Journal of the American Medical Association (JAMA), and the Prevention TaskForce app as follows:

## Efforts to Fill USPSTF Research Gaps

### Key Research Gaps for Clinical Preventive Services Across the Lifespan, in All Communities

For each recommendation, regardless of whether the recommendation receives a letter grade or has insufficient evidence and receives an “I statement,” the USPSTF routinely calls attention to evidence gaps and highlights areas where research is needed in the “Research Gaps and Needs” section of the recommendation and, whenever possible, an “Evidence Gaps Research Taxonomy Table,” which was introduced in November 2023. Both the Research Gaps and Needs section of the recommendation and the Evidence Gaps Research Taxonomy Table include evidence gaps mapped to the analytic framework. However, the Taxonomy Table provides additional guidance to the research community on how the gaps can be filled, providing the following details:

- Key Questions or Contextual Questions to outline the additional evidence the USPSTF needs to develop recommendations
- Details on how the gaps are linked, directly or indirectly, to the analytic framework
- Details on the type of gap
  – Moving from an I statement to a letter grade
  – Change in letter grade (e.g., from C to B or C to D)
  – Health equity (e.g., populations with a disproportionate burden of the condition)
  – General gap (e.g., uptake of a clinical preventive service)
- Study characteristics: research methods and specific procedures for collecting and analyzing data
- Population: the group of individuals that are of interest or specific characteristics, including underserved populations and those groups disproportionately affected by a health condition
- Intervention/comparison: the treatment to be given and the reference group to compare with the intervention
- Outcomes/timing: how the results are measured to assess the intervention’s effectiveness and for how long data should be collected
- Setting: the setting for the study (i.e., primary care)

In alignment with the USPSTF’s commitment to advancing health equity, the Task Force hopes this systematic approach to communicating evidence gaps for funders and researchers will improve filling evidence gaps that affect health inequities. The USPSTF will continue to revise and identify best practices for articulating evidence gaps and future research needs in the upcoming years.