# CLINICAL PREVENTIVE SERVICES WHERE MORE RESEARCH IS NEEDED: PROMOTING HEALTH ACROSS THE LIFESPAN, IN ALL COMMUNITIES

“We believe all infants, children, adolescents, and young adults deserve equitable, high-quality pediatric healthcare. When the USPSTF issues pediatric-focused recommendations, it directly impacts our ability to provide the highest quality care to children. The National Association of Pediatric Nurse Practitioners highly values how the Task Force outlines critical gaps in research for preventing disease and improving child health outcomes. Addressing important gaps in the evidence will allow the USPSTF to continue to develop evidence-based recommendations that help our members provide the best care to our Nation’s youth.”

Daniel Crawford, DNP, ARNP, CPNP-PC, CNE, FAANP

President

National Association of Pediatric Nurse Practitioners

The USPSTF was established in 1984 to systematically review the scientific evidence for clinical preventive services and make recommendations for primary care clinicians. To fulfill its mission to improve health by making evidence-based recommendations for preventive services, the USPSTF routinely highlights the most critical evidence gaps for making actionable preventive services recommendations. This includes calling attention to areas where evidence is lacking for populations that are disproportionately affected by health conditions.

There are two ways that the USPSTF highlights evidence gaps in its recommendation statements:

- Issuing an “I statement.” The USPSTF issues an “I statement” when the current evidence is lacking, of poor quality, or conflicting. When the evidence is insufficient, the USPSTF is unable to assess the balance of benefits and harms of the preventive service.
- Describing the “Research Needs and Gaps.” In all recommendation statements, the USPSTF points out where gaps in the evidence remain in a section called “Research Needs and Gaps.”

In 2023, the USPSTF updated the “Research Needs and Gaps” section to better summarize key bodies of evidence needed to make a recommendation. The Evidence Gaps Research Taxonomy Table provides guidance to researchers and funders on the types of studies needed to expand the evidence to enable the USPSTF to make an evidence-based recommendation in the primary care setting and be inclusive of populations disproportionately affected. Studies addressing these gaps should do the following:

- Examine preventive services conducted in the primary care setting or that are referable from primary care
- Compare outcomes for people who do and do not receive the preventive service
- Include populations without recognized signs or symptoms of the condition
- Adopt a rigorous study design appropriate for the question, such as a randomized, controlled trial or a high-quality observational study
- Be free of potential sources of bias, such as high dropout rates among participants, biased assessment of outcomes, or heterogeneity in outcome measures

To develop recommendations that improve the health of people nationwide, the USPSTF needs high-quality evidence about the benefits and harms of the preventive service and about the ways specific population groups are affected. For some preventive services and for certain populations, lack of scientific evidence limits the ability of the Task Force to make recommendations. This is because particular populations are frequently not well represented in health research. Some examples include:

- Specific age groups, including children, adolescents, and older adults
- Racial and ethnic groups historically underrepresented in research and disproportionately affected by health conditions, such as Black, Hispanic/Latino, Indigenous American, and Asian American people
- People who are lesbian, gay, bisexual, transgender, queer (LGBTQ+)
- Individuals disproportionately affected by genetic, environmental, and social risk factors, such as financial strain or lack of access to affordable care

The Task Force is prioritizing topics that are likely to advance health equity and is calling for more research for some preventive services where the lack of scientific evidence limits its ability to make recommendations. In turn, this can help inform future recommendations, improve access to and use of preventive services, reduce disparities in healthcare, and increase health equity.

## Focusing on Promoting Health Across the Lifespan, in All Communities

For this 2024 report, the USPSTF commemorates 40 years of making evidence-based recommendations about preventive services and calls attention to high-priority research gaps in the past year, with a continued focus on promoting the health of people nationwide, across the lifespan, in all communities.

Preventive services are critical for maintaining optimal health and well-being throughout the lifespan. Preventive services, such as screenings, preventive medicines, and counseling, facilitate the prevention or early detection of health issues. Early detection can lead to early intervention and better treatment outcomes, often preventing the progression of diseases and reducing the risk of disease complications.^8,9^ Combining these types of preventive services with a healthy lifestyle can substantially reduce the risk for diseases, disabilities, and death.^8,9^

For 40 years, the Task Force recommendations have played a crucial role in promoting health and healthy behaviors across the lifespan. Each encounter with a patient and/or caregiver provides an opportunity for healthcare professionals to engage in a health promotion discussion, helping to assess needs, preferences, and readiness for change and recommending appropriate preventive care services. In the past year, the Task Force has called attention to high-priority research gaps related to promoting health across the lifespan, in all communities (Table 2).

Table 2 Key Research Gaps for Clinical Preventive Services From the Past Year—Promoting Health Across the Lifespan, in All Communities

USPSTF Recommendation | Gaps Where Research Is Needed
Primary Care Interventions to Prevent Child Maltreatment | Studies are needed that provide more information to:; - Help primary care clinicians accurately identify families who might benefit from supportive interventions that may prevent child maltreatment.; - Determine if accuracy of risk assessment tools differs by social factors and race and ethnicity.; - Understand the optimal frequency of risk assessment considering chronicity, duration, intermittency, and severity of maltreatment.; - Evaluate the effectiveness of primary care–feasible or referable preventive interventions designed to reduce exposure to maltreatment, including neglect.; - Determine whether intervention effectiveness or child maltreatment reporting differs by social factors and race and ethnicity.; - Evaluate the effectiveness of interventions using more accurate outcome measures that limit bias (e.g., surveillance).; - Consistently provide outcome measure definitions, outcome types, and outcome timing across studies.; - Identify the most effective ways to prevent child maltreatment (using more accurate outcome measures), including interventions that address the social determinants of health that can negatively affect families.; - Determine whether there are unintended harms from risk assessment (e.g., stigma or legal risks related to Child Protective Services) and engagement in preventive interventions (e.g., risk of biased reporting for maltreatment).; - Understand whether potential harms differ in children by social factors and race and ethnicity.
Screening for Speech and Language Delay and Disorders in Children | Studies are needed that provide more information on:; - Treatment of screen-detected populations that follow children over short and longer (>1 year) durations to detect improvement in outcomes such as academic performance, social and emotional health, or child and family wellbeing. These studies should focus on enrolling children from groups with the greatest burden of speech and language delay and disorders (Black and Hispanic/Latino children and children from households with low incomes).; - Standardization of outcome measurement across studies.; - The potential harms of screening and treatment such as labeling, stigma, parent anxiety, other psychosocial harms, and overdiagnosis.
Interventions for High Body Mass Index in Children and Adolescents | Studies are needed that provide more information on:; - The benefits of behavioral and pharmacotherapy interventions on long-term health outcomes (at least 2 years).; - The long-term harms (at least 2 years) of pharmacotherapy.; - The long-term harms of behavioral interventions. Research is needed on the comparative benefits and harms of weight-loss versus weight-neutral healthy lifestyle interventions in children and adolescents with a high body mass index.; - The best timing for interventions for weight management and to understand whether there are certain ages in childhood and adolescence when interventions might provide a higher likelihood of treatment benefit. Research is also needed on the maintenance of weight loss after behavioral interventions and assessment of long-term (>5 years) benefits and harms.; - The best practices for initial and ongoing weight-related discussions with children and adolescents and their families.
Screening and Preventive Interventions for Oral Health in Children, Adolescents, and Adults | Studies are needed that provide more information on:; - The effectiveness and harms of primary care–based oral health screening strategies on oral health outcomes.; - The diagnostic accuracy of oral health examinations and risk assessment tools in the primary care setting to identify children ages 5 to 17 years and adults with oral health conditions.; - The accuracy of primary care–based oral health examinations and risk assessment tools to identify children ages 5 to 17 years and adults at increased risk of oral health conditions.; - The effectiveness and harms of preventive interventions, including but not limited to, fluoride gel, fluoride varnish, sealants, silver diamine fluoride, and xylitol in the primary care setting on oral health conditions.; - The effectiveness and harms of oral health education and behavioral counseling interventions on oral health outcomes.
Screening and Supplementation for Iron Deficiency and Iron Deficiency Anemia During Pregnancy | Studies are needed that provide more information on:; - Whether changes in maternal iron status (e.g., because of supplementation or treatment for screen-detected populations) improve maternal and infant health outcomes in settings relevant to U.S. primary care clinical practice.; - The benefits and harms of screening (e.g., with hemoglobin, hematocrit, or ferritin values) for iron deficiency and iron deficiency anemia during pregnancy on maternal (e.g., quality of life or need for transfusion) and infant (e.g., low birth weight or preterm birth) health outcomes.; - The benefits and harms of treatment (e.g., oral or intravenous iron) in asymptomatic, screen-detected populations with iron deficiency and iron deficiency anemia during pregnancy on maternal and infant health outcomes in settings relevant to U.S. primary care clinical practice.; - The benefits and harms of routine iron supplementation in asymptomatic pregnant persons without known iron deficiency or iron deficiency anemia on maternal and infant health outcomes.; - The relationship between social determinants of health and risk factors for iron deficiency and iron deficiency anemia, including but not limited to, nutritional status, screening services, access to iron-rich foods, and access to prenatal care and timely healthcare in populations disproportionately affected by iron deficiency/iron deficiency anemia during pregnancy.
Screening for Breast Cancer | Studies are needed that provide more information on:; - The benefits and harms of screening for breast cancer in women age 75 years or older.; - The best strategy for breast cancer screening in women found to have dense breasts on a screening mammogram, which occurs in more than 40% of women screened.; - The benefits and harms of supplemental screening (e.g., ultrasonography, MRI [magnetic resonance imaging], or contrast-enhanced mammography) compared with usual care (digital breast tomosynthesis or digital mammography alone) for women with dense breasts.; - Reasons for higher breast cancer mortality among Black women.; - Why Black women are more likely to be diagnosed with breast cancers that have biomarker patterns that confer greater risk for poor health outcomes.; - How variations in care (including diagnosis and treatment) lead to increased risk of breast cancer morbidity and mortality in Black women, across the spectrum of stages and biomarker patterns, and on effective strategies to reduce this disparity.; - Whether the benefits differ for annual versus biennial breast cancer screening among women overall and whether there is a different balance of benefits and harms among Black women compared with all women.; - Approaches to reduce the risk of overdiagnosis leading to overtreatment of breast lesions identified through screening that may not be destined to cause morbidity and mortality, including ductal carcinoma in situ (DCIS).; - The natural history of DCIS and to identify prognostic indicators to distinguish DCIS that is unlikely to progress to invasive breast cancer.
Interventions for Falls Prevention in CommunityDwelling Older Adults | Studies are needed that provide more information on:; - Feasible risk assessment tools that accurately predict risk for falls in community-dwelling adults age 65 years or older.; - The comparison of benefits and harms of exercise plus multifactorial interventions with exercise interventions alone.; - Methods to improve the availability and accessibility of effective fall prevention interventions (e.g., remote provision of intervention).; - The effectiveness and harms of interventions in different functional groups (e.g., persons with frailty).; - The benefits and harms of educational and psychological interventions.

## Primary Care Interventions to Prevent Child Maltreatment

“Since 1976, the Office of Disease Prevention and Health Promotion has supported efforts to help people live healthy and active lives. USPSTF recommendations give people the information that they need to make informed decisions for their health, but as highlighted in this report, there are still critical gaps in the evidence. Heeding the USPSTF’s call for more research and filling these gaps will help to further both of our goals of advancing health equity and improving the health of all people nationwide.”

Carter Blakey

Deputy Director

Office of Disease Prevention and Health Promotion

U.S. Department of Health and Human Resources

Child maltreatment, which includes child abuse and neglect, can have profound effects on health, development, survival, and well-being throughout childhood and adulthood.^10,11^ The prevalence of child maltreatment in the United States is uncertain and likely underestimated.^10^ In 2021, an estimated 600,000 children were identified by Child Protective Services (CPS) as experiencing abuse or neglect and an estimated 1,820 children died of abuse and neglect.^12^

The USPSTF identified research needs to address high-priority gaps and expand the evidence in primary care interventions to prevent child maltreatment, inclusive of populations disproportionately affected:

- Research is needed to help primary care clinicians accurately identify families who might benefit from supportive interventions that may prevent child maltreatment.
- Research is needed to determine if accuracy of risk assessment tools differs by social factors and race and ethnicity.
- Research is needed to understand the optimal frequency of risk assessment considering chronicity, duration, intermittency, and severity of maltreatment.
- Studies are needed to evaluate the effectiveness of primary care–feasible or referable preventive interventions designed to reduce exposure to maltreatment, including neglect.
- Research is needed to determine whether intervention effectiveness or child maltreatment reporting differs by social factors and race and ethnicity.
- Studies evaluating the effectiveness of interventions using more accurate outcome measures that limit bias (e.g., surveillance) are needed.
- In addition, consistency in outcome measure definitions, outcome types, and outcome timing across studies is needed.
- Research is needed on the most effective ways to prevent child maltreatment (using more accurate outcome measures), including interventions that address the social determinants of health that can negatively affect families.
- Research is needed to determine whether there are unintended harms from risk assessment (e.g., stigma or legal risks related to CPS) and engagement in preventive interventions (e.g., risk of biased reporting for maltreatment).
- Research is needed to understand whether potential harms differ in children by social factors and race and ethnicity.

## Screening for Speech and Language Delay and Disorders in Children

Speech and language delay and disorders can pose significant problems for children and their families. Evidence suggests that school-aged children with speech or language delays may be at increased risk of learning and literacy disabilities, including difficulties with reading and writing.^13–15^ Observational cohort studies suggest that children with these conditions may also be at higher risk for social and behavioral problems in addition to learning problems, some of which may persist through adulthood.^16^ Research is needed to determine whether identifying speech and language delays early (i.e., in children age 5 years or younger) and providing interventions helps prevent these issues before they interfere with school learning or psychosocial adjustment.

The USPSTF identified high-priority gaps to be addressed and expand the evidence in screening for speech and language delay and disorders in children, inclusive of populations disproportionately affected:

- Treatment studies are needed of screen-detected populations that follow children over short and longer (>1 year) durations to detect improvement in outcomes such as academic performance, social and emotional health, or child and family well-being. These studies should focus on enrolling children from groups with the greatest burden of speech and language delay and disorders (Black and Hispanic/Latino children and children from households with low incomes).
- Standardization of outcome measurement across studies is needed.
- Studies are needed on the potential harms of screening and treatment such as labeling, stigma, parent anxiety, other psychosocial harms, and overdiagnosis.

## Interventions for High Body Mass Index in Children and Adolescents

Approximately 19.7% of children and adolescents ages 2 to 19 years in the United States have a body mass index (BMI) at or above the 95th percentile for age and sex, based on Centers for Disease Control and Prevention (CDC) growth charts from 2000.^17,18^ BMI percentile is plotted on growth charts, such as those developed by the CDC, which are based on U.S.-specific, population-based norms for children age 2 years or older.^17,19^ The prevalence of high BMI increases with age and is higher among Hispanic/Latino, Indigenous American, and non-Hispanic Black children and adolescents and children from lower-income families.^17,18^

The USPSTF identified high-priority gaps to expand the evidence in interventions for high body mass index BMI in children and adolescents, inclusive of populations disproportionately affected:

- Research is needed on long-term health outcomes (at least 2 years) and the benefits of behavioral and pharmacotherapy interventions.
- Research is needed on long-term (at least 2 years) psychosocial harms (e.g., quality of life) of pharmacotherapy.
- Research is needed on the benefits and harms of healthy lifestyle or weight-neutral interventions in children and adolescents with a high BMI.
- Research is needed on the best timing for interventions for weight management.
- Research is needed on the maintenance of weight loss after behavioral interventions and assessment of long-term (>5 years) benefits and harms.
- Research is needed on the best practices for weight-related discussions with children and adolescents and their families.
- Research is needed on the biochemical adaptations to weight loss in children and adolescents that may promote weight regain.

## Screening and Preventive Interventions for Oral Health in Children, Adolescents, and Adults

Oral health is fundamental to overall health and well-being across the lifespan.^20,^ ^21^ Oral health conditions affect the daily lives of school-age children and adolescents, leading to the loss of more than 51 million school hours every year.^22,23^ Despite declines in untreated tooth decay in the primary teeth of young children,^24,25^ dental caries remains one of the most common conditions of childhood, and the prevalence of untreated caries increases as children age.^20,21,26^ Dental caries can negatively affect a range of outcomes, including but not limited to, eating, speaking, learning, smiling, self-esteem, and quality of life.^20^ Untreated oral health conditions can lead to tooth loss, irreversible tooth damage, and other serious adverse health outcomes.^20,24^

In the United States, oral health disparities are shaped by inequities in the affordability and accessibility of dental care and other disadvantages related to social determinants of health (e.g., living in a rural area or immigration status).^20,21,23,24^ Dental caries and periodontitis disproportionately affect Asian, Black, Hispanic/Latino, and Indigenous American children, adolescents, and adults; children with special healthcare needs;^20^ adults with disabilities; adults age 65 years or older or living in institutional settings; adults living in rural and urban underserved areas; adults without insurance or with public insurance; and adults experiencing homelessness.^20,21^ Additional risk factors for developing oral health problems include lack of brushing and flossing teeth, high sugar diets from beverages and food, low fluoride exposure, tobacco use, and developmental defects in teeth.

The USPSTF research needs to address high-priority gaps and expand the evidence in screening and preventive interventions for oral health in children ages 5 to 17 years and adults, inclusive of populations disproportionately affected:

- Research is needed to assess the effectiveness and harms of primary care–based oral health screening strategies on oral health outcomes.
- Research is needed to assess the diagnostic accuracy of oral health examinations and risk assessment tools in the primary care setting to identify those with oral health conditions.
- Research is needed to assess the effectiveness and harms of preventive interventions, including but not limited to, fluoride gel, fluoride varnish, sealants, silver diamine fluoride, and xylitol in the primary care setting on oral health conditions.
- Research is needed to assess the effectiveness and harms of oral health education and behavioral counseling interventions on oral health outcomes.
- Research is needed to identify the effectiveness of strategies that can be delivered in primary care settings to improve quality of life, function, or other clinically important oral health outcomes.

## Screening and Supplementation for Iron Deficiency and Iron Deficiency Anemia During Pregnancy

Iron deficiency is the leading cause of anemia during pregnancy.^27^ According to National Health and Nutrition Examination Survey data from 1999 to 2006, the overall estimated prevalence of iron deficiency during pregnancy is near 18% and increases across the three trimesters of pregnancy (from 6.9% to 14.3% to 28.4%).^28^ An estimated 5% of pregnant persons have iron deficiency anemia.^27,28^ In the United States, there are disparities in the prevalence of iron deficiency anemia by race, ethnicity, and social factors (e.g., socioeconomic status, nutritional status, and food insecurity).^27,28^ The aim of routine screening or iron supplementation for treatment of iron deficiency and iron deficiency anemia during pregnancy is to improve maternal and infant health outcomes.

The USPSTF needs research to address high-priority gaps and expand the evidence in screening and supplementation for iron deficiency and iron deficiency anemia during pregnancy, inclusive of populations disproportionately affected:

- Research is needed in pregnant persons with iron deficiency and iron deficiency anemia to assess whether changes in maternal iron status (e.g., because of supplementation or treatment for screen-detected populations) improve maternal and infant health outcomes in settings relevant to U.S. primary care clinical practice.
- Research is needed to assess the benefits and harms of screening (e.g., with hemoglobin, hematocrit, or ferritin values) for iron deficiency and iron deficiency anemia during pregnancy on maternal (e.g., quality of life or need for transfusion) and infant (e.g., low birth weight or preterm birth) health outcomes.
- Research is needed to assess the benefits and harms of treatment (e.g., oral or intravenous iron) in asymptomatic, screen-detected populations with iron deficiency and iron deficiency anemia during pregnancy on maternal and infant health outcomes in settings relevant to U.S. primary care clinical practice.
- Research is needed to assess the benefits and harms of routine iron supplementation in asymptomatic pregnant persons without known iron deficiency or iron deficiency anemia on maternal and infant health outcomes.
- Research is needed to assess the relationship between social determinants of health and risk factors for iron deficiency and iron deficiency anemia, including but not limited to nutritional status, screening services, access to iron-rich foods, and access to prenatal care and timely healthcare in populations disproportionately affected by iron deficiency/iron deficiency anemia during pregnancy.

## Screening for Breast Cancer

Among all U.S. women, breast cancer is the second most common cancer and the second most common cause of cancer death. In 2023, an estimated 43,170 women died of breast cancer.^29^ Non-Hispanic White women have the highest incidence of breast cancer (5-year age-adjusted incidence rate, 136.3 cases per 100,000 women), and non-Hispanic Black women have the second highest incidence rate (5-year age-adjusted incidence rate, 128.3 cases per 100,000 women).^30^ Incidence gradually increased among women ages 40 to 49 years from 2000 to 2015 but increased more noticeably from 2015 to 2019, with a 2.0% average annual increase.^31^ Despite having a similar or higher self-reported rate of mammography screening,^32^ Black women are more likely to be diagnosed with breast cancer beyond stage I than other racial and ethnic groups, are more likely to be diagnosed with triple-negative cancers (i.e., estrogen receptor–negative [ER–], progesterone receptor–negative [PR–], and human epidermal growth factor receptor 2–negative [HER2–]), which are more aggressive tumors, compared with White women,^33^ and are approximately 40% more likely to die of breast cancer compared with White women.^34^

Despite new research that led to the Task Force recommending all women get a mammogram starting at the age of 40, the USPSTF identified research needs to address several high-priority gaps to expand the evidence in screening for breast cancer, inclusive of populations disproportionately affected:

- Research is needed to determine the benefits and harms of screening for breast cancer in women age 75 years or older.
- Research is needed to help clinicians and patients understand the best strategy for breast cancer screening in women found to have dense breasts on a screening mammogram, which occurs in more than 40% of women screened.
  – Research is needed to determine the benefits and harms of supplemental screening (e.g., ultrasonography, MRI [magnetic resonance imaging], or contrast-enhanced mammography) compared with usual care (digital breast tomosynthesis or digital mammography alone) for women with dense breasts.
- Research is needed to understand and address the higher breast cancer mortality among Black women.
  – Research is needed to understand why Black women are more likely to be diagnosed with breast cancers that have biomarker patterns that confer greater risk for poor health outcomes.
  – Research is needed to understand how variations in care (including diagnosis and treatment) lead to increased risk of breast cancer morbidity and mortality in Black women across the spectrum of stages and biomarker patterns, and on effective strategies to reduce this disparity.
  – Research is needed to determine whether the benefits differ for annual versus biennial breast cancer screening among women overall and whether there is a different balance of benefits and harms among Black women compared with all women.
- Research is needed to identify approaches to reduce the risk of overdiagnosis leading to overtreatment of breast lesions identified through screening that may not be destined to cause morbidity and mortality, including ductal carcinoma in situ (DCIS).
  – Research is needed on the natural history of DCIS and to identify prognostic indicators to distinguish DCIS that is unlikely to progress to invasive breast cancer.

## Interventions for Falls Prevention in Community-Dwelling Older Adults

Falls are the leading cause of injury-related morbidity and mortality among older adults in the United States.^35^ In 2018, 27.5% of community-dwelling adults age 65 years or older reported at least one fall in the past year (714 falls per 1,000 older adults), and 10.2% reported a fall-related injury (170 fall-related injuries per 1,000 older adults).^36^ Indigenous American older adults reported more falls (32.2%) and fall-related injuries (15.2%) compared with other racial and ethnic groups. Stratified by age, 25.9% of adults ages 65 to 74 years reported falling and 9.3% reported fall-related injuries; 28.5% of adults ages 75 to 84 years reported falling and 10.6% reported fall-related injuries; and 33.8% of adults age 85 years or older reported falling and 13.9% reported fall-related injuries.^36^ In 2021, an estimated 38,742 deaths resulted from fall-related injuries.^33^ Most fall-related deaths occur in adults age 85 years or older; this group also has the fastest-growing rate of death from falls.^36,37^

The USPSTF identified high-priority gaps related to interventions for falls prevention in community-dwelling older adults, inclusive of populations disproportionately affected:

- Research is needed to develop and validate primary care–feasible risk assessment tools that accurately predict risk for falls in community-dwelling adults age 65 years or older.
- Studies are needed that compare the benefits and harms of exercise plus multifactorial interventions with exercise interventions alone.
- Studies are needed on methods to improve the availability and accessibility of effective fall prevention interventions (e.g., remote provision of intervention).
- Studies are needed on the effectiveness and harms of interventions in different functional groups (e.g., persons with frailty).
- More studies are needed on the benefits and harms of educational and psychological interventions.