# BACKGROUND

Clinical preventive services are available for many diseases and conditions, including strategies that intervene before a disease occurs (primary prevention) and detecting a disease at an early stage (secondary prevention) for early intervention and treatment.^3,4^ These clinical preventive services have tremendous value in improving health throughout the lifespan.

The Task Force makes recommendations to help primary care clinicians, patients, and families decide together whether a particular preventive service is right for an individual’s needs. Task Force recommendations:

- Apply only to people without recognized signs or symptoms of the disease or health condition
- Focus on counseling, screening, or medications to prevent the onset of disease or identify disease early when it is more treatable
- Address services offered in the primary care setting or services to which patients can be referred by primary care professionals

Since 1998, the Agency for Healthcare Research and Quality (AHRQ) has been authorized by Congress to convene the Task Force and to provide ongoing scientific, administrative, and dissemination support. AHRQ funds Evidence-based Practice Centers (EPCs), which are academic or research organizations that work with the Task Force to develop research plans and conduct the evidence reviews that the Task Force uses to inform its recommendations.

## Who Serves on the Task Force?

The USPSTF is an independent group of national experts in prevention and evidence-based medicine who represent the diverse disciplines of primary care, including behavioral health, family medicine, geriatrics, internal medicine, nursing, obstetrics and gynecology, preventive medicine, and pediatrics. The Task Force is made up of 16 volunteer members who are appointed to serve 4-year terms, led by a chair and two vice chairs (see Appendix A for current members).

## How Does the Task Force Minimize Potential Conflicts of Interest?

To ensure that USPSTF recommendations are balanced, independent, and objective, the Task Force has a long-standing and rigorous conflict of interest assessment and disclosure process.^5^ The process for each member begins prior to appointment, and potential conflicts of interest are also reviewed at least three times each year.

## How Does the Task Force Make Recommendations?

The Task Force’s recommendations are based on a review of the best available research on the potential benefits and harms of the preventive service. The USPSTF does not conduct research studies but rather reviews and assesses published research. The Task Force follows a multistep process when developing each of its recommendations and obtains public input throughout the recommendation development process (see Figure 1).

Figure 1 Steps the USPSTF Takes to Make a Recommendation

When the Task Force reviews the evidence, it considers the benefits and harms of the preventive service for the overall population, as well as for specific segments of the U.S. population that may be disproportionately affected by a condition or that may benefit differently from the preventive service.^6^

Potential benefits of preventive services may include helping people stay healthy throughout their lifetime, improving quality of life, preventing disease, and prolonging life. Potential harms may include inaccurate test results, harms from invasive followup tests, harms from treatment of a disease or condition, diagnosis of a condition that would never have caused symptoms or problems in a person’s lifetime (also known as “overdiagnosis”) or receiving treatment when it is not needed or may not actually improve health (also known as “overtreatment”).

The Task Force assigns each of its recommendations a letter grade (A, B, C, or D) or issues an “I statement” based on the certainty of the evidence and the balance of benefits and harms of the preventive service (see Table 1 for the Grade Definitions).

Table 1 Meaning of USPSTF Grades

Grade | Definition
A | The USPSTF recommends the service. There is high certainty that the net benefit is substantial
B | The USPSTF recommends the service. There is high certainty that the net benefit is moderate or there is moderate certainty that the net benefit is moderate to substantial.
C | The USPSTF recommends selectively offering or providing this service to individual patients based on professional judgment and patient preferences. There is at least moderate certainty that the net benefit is small.
D | The USPSTF recommends against the service. There is moderate or high certainty that the service has no net benefit or that the harms outweigh the benefits.
I Statement | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of the service. Evidence is lacking, of poor quality, or conflicting, and the balance of benefits and harms cannot be determined.

## How Does the Task Force Engage the Public, Partners, Stakeholders, and Topic Experts in Developing Recommendations?

For each topic, the USPSTF actively seeks input from the public, its partners, stakeholders, and topic experts, including medical specialists—such as radiologists, oncologists, cardiologists, surgeons, and others. This ensures a focus on important clinical prevention topics for practicing clinicians and that the evidence relevant to each recommendation is considered.^7^ At each step of the recommendation development process, the USPSTF solicits and reviews input. Anyone—the public, USPSTF partners, stakeholders, and topic experts—can nominate a new topic or propose an update to an existing topic, as well as submit comments on all Task Force draft materials (research plans, evidence reviews, and recommendation statements).

- The Public. All draft materials are posted on the Task Force website for a 4-week public comment period. The Task Force reviews and considers all comments as it finalizes the materials. Any organizations or individuals interested in being informed of Task Force activities can subscribe to the U.S. Preventive Services Task Force email list to receive announcements on opportunities to provide public comment on draft materials, notifications of when final materials are posted or published, and information about other Task Force activities.
- Partners. The Task Force works with national organizations that represent primary care clinicians (including organizations that represent specific populations working to advance health equity), consumers, and other primary care stakeholders and health-related Federal agencies. These organizations and agencies provide input on the recommendations as they are being developed and help the Task Force disseminate the final recommendations (see Appendices B and C for a list of partners).
- Stakeholders. The Task Force identifies relevant stakeholder groups for each topic and contacts their leadership, inviting them to comment on the drafts during the public comment periods. Stakeholder groups include national primary care, specialty, patient, advocacy, and other organizations with expertise and interest in a specific topic.
- Topic experts. The Task Force seeks input from different types of topic experts, including medical specialists such as radiologists, oncologists, cardiologists, and surgeons. In addition, the EPC team that conducts the evidence reviews for each topic always includes content experts who work with the EPC during the systematic evidence review. Expert reviewers provide input on the evidence supporting the draft recommendation statement.

## Where Can I Find More Information About the Task Force?

The Task Force website (www.uspreventiveservicestaskforce.org) contains more information about the Task Force and its methods for developing recommendations, including engaging with experts, partners, and the public. More details are available on the “Task Force at a Glance (https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/task-force-at-a-glance)” and “Methods and Processes (https://www.uspreventiveservicestaskforce.org/uspstf/index.php/about-uspstf/methods-and-processes)” pages.