# INTRODUCTION

“The American College of Preventive Medicine is dedicated to promoting the importance of preventive medicine. The USPSTF helps to achieve this by providing evidence-based guidance on how to prevent disease and promote good health. We applaud the USPSTF for focusing this year’s report on the high-priority research gaps related to promoting health across the lifespan and in all communities. We hope that future research addresses these gaps to help further our efforts to advance the health and well-being of all people and communities.”

Melissa Ferrari, CAE

Interim CEO

American College of Preventive Medicine

The U.S. Preventive Services Task Force (USPSTF or Task Force) is an independent, volunteer group of national experts in prevention, primary care, and evidence-based medicine. For 40 years, the Task Force has made evidence-based recommendations about clinical preventive services that can be delivered or referred from primary care to improve the health of people nationwide (e.g., by improving quality of life and prolonging life). These recommendations include screening tests, behavioral counseling, and preventive medications.

The mission of the USPSTF is to improve the health of people nationwide by making evidence-based recommendations about clinical preventive services.

The purpose of this report is to update Congress and the research community about high-priority evidence gaps in clinical preventive services identified by the Task Force in the past year that, if filled, have the potential to promote health across the lifespan, in all communities.