# Appendix F 40th Anniversary Timeline

## Celebrating 40 years of Prevention Guidance

For 40 years, the [underlined: U.S. Preventive Services Task Force] (USPSTF or Task Force) has improved the health of people nationwide by making evidence-based recommendations on preventive services. Clinicians, healthcare professionals, patients, families, and communities all look to the Task Force to help them know what works and what doesn’t in preventive care. Join us as we celebrate 40 years of this important work!