# Appendix D USPSTF Final Recommendations Published October 2023–September 2024

Over the past year, the members of the Task Force continued working on a full portfolio of topics. It published 8 final recommendation statements with 14 recommendation grades in a peer-reviewed journal between October 1, 2023, and September 30, 2024. For a complete listing of all current USPSTF recommendations, see the USPSTF website (https://www.uspreventiveservicestaskforce.org/).

Appendix D Table Final Recommendation Statements Published by the USPSTF, October 1, 2023, to September 30, 2024

Topic | Recommendation
Interventions for High Body Mass Index in Children and Adolescents | The USPSTF recommends that clinicians provide or refer children and adolescents 6 years or older with a high body mass index (BMI) (≥95th percentile for age and sex) to comprehensive, intensive behavioral interventions. (Grade B)
Interventions to Prevent Falls in Community-Dwelling Older Adults | The USPSTF recommends exercise interventions to prevent falls in community-dwelling adults 65 years or older who are at increased risk for falls. (Grade B); The USPSTF recommends that clinicians individualize the decision to offer multifactorial interventions to prevent falls to community-dwelling adults 65 years or older who are at increased risk for falls. Existing evidence indicates that the overall net benefit of routinely offering multifactorial interventions to prevent falls is small. When determining whether this service is appropriate for an individual, patients and clinicians should consider the balance of benefits and harms based on the circumstances of prior falls, presence of comorbid medical conditions, and the patient’s values and preferences. (Grade C)
Primary Care Interventions to Prevent Child Maltreatment | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of primary care interventions to prevent child maltreatment. (I statement)
Screening and Preventive Interventions for Oral Health in Adults | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of routine screening performed by primary care clinicians for oral health conditions, including dental caries or periodontal-related disease, in adults. (I statement); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of preventive interventions performed by primary care clinicians for oral health conditions, including dental caries or periodontal-related disease, in adults. (I statement)
Screening and Preventive Interventions for Oral Health in Children and Adolescents Ages 5 to 17 Years | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of routine screening performed by primary care clinicians for oral health conditions, including dental caries, in children and adolescents ages 5 to 17 years. (I statement); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of preventive interventions performed by primary care clinicians for oral health conditions, including dental caries, in children and adolescents ages 5 to 17 years. (I statement)
Screening and Supplementation for Iron Deficiency and Iron Deficiency Anemia During Pregnancy | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for iron deficiency and iron deficiency anemia in pregnant persons to prevent adverse maternal and infant health outcomes. (I statement); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of routine iron supplementation in pregnant persons to prevent adverse maternal and infant health outcomes. (I statement)
Screening for Breast Cancer | The USPSTF recommends biennial screening mammography for women ages 40 to 74 years. (Grade B); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening mammography in women 75 years or older. (I statement); The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of supplemental screening for breast cancer using breast ultrasonography or magnetic resonance imaging (MRI) in women identified to have dense breasts on an otherwise negative screening mammogram. (I statement)
Screening for Speech and Language Delay and Disorders in Children | The USPSTF concludes that the current evidence is insufficient to assess the balance of benefits and harms of screening for speech and language delay and disorders in children 5 years or younger. (I statement)