# Appendix C Federal Liaisons to the USPSTF (2024)

- Centers for Disease Control and Prevention
- Centers for Medicare & Medicaid Services
- Department of Defense Military Health System
- Department of Health and Human Services, Office of Minority Health
- Department of Veterans Affairs National Center for Health Promotion and Disease Prevention
- Health Resources and Services Administration
- Indian Health Service
- National Cancer Institute
- National Institutes of Health
- Office of the Assistant Secretary for Health, Office of Disease Prevention and Health Promotion
- Substance Abuse and Mental Health Services Administration
- U.S. Food and Drug Administration