# Appendix B USPSTF Dissemination and Implementation Partner Organizations (2024)

- AARP
- American Academy of Family Physicians
- American Academy of Pediatrics
- American Academy of Physician Associates
- American Association of Nurse Practitioners
- American College of Nurse-Midwives
- American College of Obstetricians and Gynecologists
- American College of Physicians
- American College of Preventive Medicine
- American Geriatrics Society
- American Medical Association
- American Osteopathic Association
- American Psychological Association
- America’s Health Insurance Plans
- Association of American Indian Physicians
- Business Group on Health
- Canadian Task Force on Preventive Health Care
- Community Preventive Services Task Force
- GLMA: Health Professionals Advancing LGBTQ Equality
- National Association of Pediatric Nurse Practitioners
- National Committee for Quality Assurance
- National Council of Asian Pacific Islander Physicians
- National Hispanic Medical Association
- National Medical Association/Cobb Institute
- Patient-Centered Outcomes Research Institute