# Appendix A Members of the USPSTF (2024)

Wanda K. Nicholson, M.D., M.P.H., M.B.A., Chair

Dr. Nicholson is professor of prevention and community health at the Milken Institute School of Public Health at the George Washington University. She is an obstetrician-gynecologist; vice president of the board of directors of the American Board of Obstetrics and Gynecology; former editor of health equity, diversity, and inclusion for the American Journal of Obstetrics and Gynecology; past chair of the American College of Obstetricians and Gynecologists (ACOG) Diversity, Equity, and Inclusive Excellence Workgroup; and an immediate past member of the executive board of ACOG. Her clinical and research focus is on healthcare prevention across the woman’s lifespan.

Michael Silverstein, M.D., M.P.H., Vice Chair

Dr. Silverstein is the George Hazard Crooker University professor of health services, policy, and practice at the Brown University School of Public Health and the director of Brown University’s Hassenfeld Child Health Innovation Institute, which is charged with eliminating health inequities in pregnancy and childhood for Rhode Island families.

John B. Wong, M.D., MACP, Vice Chair

Dr. Wong is vice chair for academic affairs, chief of the Division of Clinical Decision Making, and a primary care internist in the Department of Medicine at Tufts Medical Center. He is also a professor of medicine at Tufts University School of Medicine.

David Chelmow, M.D., Member

Dr. Chelmow is the Leo J. Dunn professor of obstetrics and gynecology and chair of the Department of Obstetrics-Gynecology at Virginia Commonwealth University (VCU) School of Medicine in Richmond, Virginia. He has been chair since 2010 and recently completed service as interim dean for the VCU School of Medicine.

Tumaini Rucker Coker, M.D., M.B.A., Member

Dr. Coker is division head of General Pediatrics and professor of pediatrics at the University of Washington School of Medicine and Seattle Children’s. She serves as the co-director of the University of Washington’s Child Health Equity Research Fellowship, which is funded by the National Institutes of Health.

Esa M. Davis, M.D., M.P.H., FAAFP, Member

Dr. Davis is a professor of family and community medicine, the associate vice president for community health at the University of Maryland Baltimore, and the senior associate dean of population and community medicine at the University of Maryland School of Medicine. She is the lead health equity strategist for the University of Maryland Institute for Health Computing. Dr. Davis is also the director of the Transforming Biomedical Research and Academic Faculty Through Leadership Opportunities, Training, and Mentorship (TRANSFORM) program.

Carlos Roberto Jaén, M.D., Ph.D., M.S., FAAFP, Member

Dr. Jaén is a professor and the Dr. and Mrs. James L. Holly distinguished chair in the Department of Family and Community Medicine at the Joe R. and Teresa Lozano Long School of Medicine at The University of Texas Health Science Center at San Antonio.

Marie Krousel-Wood, M.D., M.S.P.H., Member

Dr. Krousel-Wood is a professor and the Jack Aron endowed chair in primary care medicine in the Tulane School of Medicine Department of Medicine. She is the founding director of the Tulane Center for Health Outcomes, Implementation, and Community-Engaged Science (CHOICES). She serves in several leadership roles at Tulane, including associate provost for the health sciences, senior associate dean of faculty in the School of Medicine, and associate dean for public health and medical education.

Sei Lee, M.D., M.A.S., Member

Dr. Lee is a professor of medicine in the Division of Geriatrics at the University of California, San Francisco, and the Senior Scholar for the San Francisco Veterans Affairs Quality Scholars fellowship. Dr. Lee also chairs the American Geriatrics Society Quality and Performance Measurement Committee. He is a geriatrician and palliative care physician and has cared for patients in the clinic, hospital, and nursing home settings.

Li Li, M.D., Ph.D., M.P.H., Member

Dr. Li is a family physician and the Walter M. Seward professor and chair of family medicine at the University of Virginia (UVA) School of Medicine. He is also co-leader of the Cancer Prevention and Population Health program at the UVA Comprehensive Cancer Center.

Goutham Rao, M.D., FAHA, Member

Dr. Rao is the chair of the Department of Family Medicine and Community Health and chief clinician experience officer for the University Hospitals (UH) Health System. He practices family medicine and leads the medical obesity treatment program. He also serves as division chief of Family Medicine at UH Rainbow Babies & Children’s Hospital. In addition, Dr. Rao is the Jack H. Medalie professor and chair of the Department of Family Medicine and Community Health at Case Western Reserve University School of Medicine.

John M. Ruiz, Ph.D., Member

Dr. Ruiz is a professor of clinical psychology in the Department of Psychology at the University of Arizona. He is also the associate director of inclusivity, diversity, equity, and accessibility (IDEA) in the University of Arizona Cancer Center.

James Stevermer, M.D., M.S.P.H., Member

Dr. Stevermer is vice chair and the Paul Revare, M.D., professor of family and community medicine at the University of Missouri (MU). He also practices and teaches rural primary care at MU Health Care Family Medicine–Callaway Physicians. His scholarly activities focus on dissemination and evidence-based medicine.

Joel Tsevat, M.D., M.P.H., Member

Dr. Tsevat is a general internist, professor of medicine, and Joaquin G. Cigarroa, Jr., M.D., distinguished chair in the Joe R. and Teresa Lozano Long School of Medicine at The University of Texas Health Science Center at San Antonio.

Sandra Millon Underwood, R.N., Ph.D., Member

Dr. Underwood is a professor emerita in the College of Nursing at the University of Wisconsin-Milwaukee. She is a nurse researcher, educator, and clinician with 40 years of experience in the design, implementation, and evaluation of evidence-based programs that aim to foster diversity, inclusion, and health equity, and improve health outcomes among diverse, underserved, at-risk population groups.

Sarah Wiehe, M.D., M.P.H., Member

Dr. Wiehe is the Jean and Jerry Bepko professor of pediatrics and associate dean of community and translational research at Indiana University School of Medicine. She is a research scientist at the Regenstrief Institute and adjunct professor of epidemiology at Fairbanks School of Public Health at Indiana University. Dr. Wiehe co-directs the Indiana Clinical and Translational Sciences Institute and leads its community engagement program.