# References

1 Ngo-Metzger Q, Moyer V, Grossman D, Conflicts of interest in clinical guidelines: update of U.S. Preventive Services Task Force policies and procedures. Am J Prev Med. 2018;54(1S1):S70–S80.29254528
2 Epling JW, Borsky AE, Gerteis J. Improvements to the US Preventive Services Task Force recommendation statement. JAMA. 2019;322(12):1143–1144.31550039
3 Bibbins-Domingo K, Whitlock E, Wolff T, Developing recommendations for evidence-based clinical preventive services for diverse populations: methods of the US Preventive Services Task Force. Ann Intern Med. 2017;166(8):565–571.28265649
4 Centers for Disease Control and Prevention. About Mental Health. Reviewed April 25, 2023. Accessed July 12, 2023. https://www.cdc.gov/mentalhealth/learn/index.htm
5 Merikangas KR, He JP, Burstein M, Lifetime prevalence of mental disorders in U.S. adolescents: results from the National Comorbidity Survey Replication--Adolescent Supplement. J Am Acad Child Adolesc Psychiatry. 2010;49(10):980–989.20855043
6 Substance Abuse and Mental Health Services Administration. Key Substance Use and Mental Health Indicators in the United States: Results From the 2018 National Survey on Drug Use and Health. HHS Publication No. PEP19–5068, NSDUH Series H-54. Rockville, MD: Center for Behavioral Health Statistics and Quality, Substance Abuse and Mental Health Services Administration; 2019.
7 National Institute of Mental Health. Chronic Illness and Mental Health: Recognizing and Treating Depression. Revised 2021. Accessed July 12,2023. https://www.nimh.nih.gov/health/publications/chronic-illness-mental-health
8 Viswanathan M, Wallace IF, Middleton JC, Screening for Depression, Anxiety, and Suicide Risk in Children and Adolescents: An Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 221. Rockville, MD: Agency for Healthcare Research and Quality; 2022.
9 Viswanathan M, Wallace IF, Cook Middleton J, Screening for anxiety in children and adolescents: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2022;328(14):1445–1455.36219404
10 Heron M. Deaths: Leading Causes for 2019. Natl Vital Stat Rep. 2021;70(9)1–114.
11 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders. 5th ed. Arlington, VA: American Psychiatric Association; 2013.
12 O’Connor E, Henninger M, Perdue LA, Coppola EL, Thomas R, Gaynes BN. Screening for Depression, Anxiety, and Suicide Risk in Adults: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 223. Rockville, MD: Agency for Healthcare Research and Quality; 2022.
13 Mayo Clinic. Depression (Major Depressive Disorder). Updated October 14, 2022. Accessed July 12, 2023. https://www.mayoclinic.org/diseases-conditions/depression/symptoms-causes/syc-20356007
14 Gilman SE, Sucha E, Kingsbury M, Horton NJ, Murphy JM, Colman I. Depression and mortality in a longitudinal study: 1952–2011. CMAJ. 2017;189(42):E1304–E1310.29061855
15 Kessler RC, Merikangas KR, Wang PS. Prevalence, comorbidity, and service utilization for mood disorders in the United States at the beginning of the twenty-first century. Annu Rev Clin Psychol. 2007;3:137–58.17716051
16 Szegda K, Markenson G, Bertone-Johnson ER, Chasan-Taber L. Depression during pregnancy: a risk factor for adverse neonatal outcomes? A critical review of the literature. J Matern Fetal Neonatal Med. 2014;27(9):960–967.24044422
17 Jarde A, Morais M, Kingston D, Neonatal outcomes in women with untreated antenatal depression compared with women without depression: a systematic review and meta-analysis. JAMA Psychiatry. 2016;73(8):826–837.27276520
18 Centers for Disease Control and Prevention. WISQARS—Web-Based Injury Statistics Query and Reporting System. Accessed September July 12, 2023. https://www.cdc.gov/injury/wisqars/index.html
19 Hedegaard H, Curtin SC, Warner M. Suicide mortality in the United States, 1999–2019. NCHS Data Brief. 2021 Feb;(398):1–8.
20 Curtin S, Hedegaard H, Ahmad FB. Provisional Numbers and Rates of Suicide by Month and Demographic Characteristics: United States, 2020. Published November 2021. Accessed July 12, 2023 https://www.cdc.gov/nchs/data/vsrr/VSRR016.pdf
21 Stone DM, Jones CM, Mack KA. Changes in suicide rates—United States, 2018–2019. MMWR Morb Mortal Wkly Rep. 2021;70(8):261–268.33630824
22 Mitchell AJ, Vaze A, Rao S. (2009). Clinical diagnosis of depression in primary care: a meta-analysis. Lancet. 2009;374(9690):609–619.19640579
23 Roberge P, Normand-Lauzière F, Raymond I, Generalized anxiety disorder in primary care: mental health services use and treatment adequacy. BMC Fam Pract. 2015;16:146.26492867
24 Wang PS, Angermeyer M, Borges G. Delay and failure in treatment seeking after first onset of mental disorders in the World Health Organization’s World Mental Health Survey Initiative. World Psychiatry. 2007;6(3):177–185.18188443
25 Bandelow B, Michaelis S. Epidemiology of anxiety disorders in the 21st century. Dialogues Clin Neurosci. 2015;17(3):327–335.26487813
26 Kessler RC, Petukhova M, Sampson NA, Zaslavsky AM, Wittchen HU. Twelve-month and lifetime prevalence and lifetime morbid risk of anxiety and mood disorders in the United States. Int J Methods Psychiatr Res. 2012;21(3):169–184 22865617
27 Misri S, Abizadeh J, Sanders S, Swift E. Perinatal generalized anxiety disorder: assessment and treatment. J Womens Health (Larchmt). 2015;24(9):762–770.26125602
28 Lin JS, Hoffman L, Bean SI, Addressing racism in preventive services: methods report to support the US Preventive Services Task Force. JAMA. 2021;326(23):2412–2420.34747987
29 US Preventive Services Task Force; Davidson KW, Mangione CM, Barry MJ, Actions to transform US Preventive Services Task Force methods to mitigate systemic racism in clinical preventive services. JAMA. 2021;326(23):2405–2411.34747970
30 National Academies of Sciences, Engineering, and Medicine. Closing Evidence Gaps in Clinical Prevention. Washington, DC: The National Academies Press; 2022.