# THE USPSTF IN 2024

In the coming 12 months, it is expected that the USPSTF will continue to:

## Develop and Release New Recommendation Statements

- Work on more than 29 topics that are in progress
- Work on 5 topics nominated for consideration through the public topic nomination process
- Post 8 draft research plans and 12 draft recommendation statements and evidence reports for public comment
- Publish 9 final recommendation statements

## Coordinate With Partners to Develop and Disseminate Recommendations

- Coordinate with the USPSTF Dissemination and Implementation Partners and Federal Liaisons to solicit input and disseminate the recommendations to primary care clinicians and other stakeholders to achieve the benefits of screening tests, behavioral counseling, and preventive medications to improve health outcomes and reduce disparities.

## Address Research Gaps

- Continue close collaboration with AHRQ and NIH’s Office of Disease Prevention to revise best practices for articulating evidence gaps and future research needs.
- Prepare the 14th Annual Report to Congress on high-priority evidence gaps (see Appendix E for a list of prior reports).

The USPSTF appreciates the opportunity to report on its activities, to highlight critical evidence gaps, and to recommend important new areas for research in clinical preventive services. The members of the Task Force look forward to their ongoing work to improve the health of people nationwide.