# THE USPSTF IN 2023 AND OTHER HIGHLIGHTS

Over the past year, the Task Force members continued working on a full portfolio of topics. The current USPSTF library includes 89 preventive service recommendation statements, with 143 specific recommendation grades. Many recommendation statements include multiple recommendation grades for different populations. In fiscal year 2023 (October 1, 2022, to September 30, 2023), the Task Force accomplished the following:

- Received 40 nominations for new topics and 9 nominations to reconsider or update existing topics
- Posted 9 draft research plans for public comment
- Posted 10 draft recommendation statements and 10 draft evidence reports for public comment
- Published 13 final recommendation statements with 11 recommendation grades in medical journals; posted 11 final evidence reports
- For a listing of all final USPSTF recommendations released since the last report, see Appendix D.

## Partner Engagement to Develop and Disseminate Recommendations

The USPSTF continued to work with its partner organizations to enhance the accuracy and relevance of its recommendations, disseminate the work of the USPSTF, and facilitate implementation of the Task Force recommendations into practice. USPSTF partner organizations include federal agencies that are stakeholders in the process and dissemination and implementation partners that represent primary care clinicians, consumers, and other stakeholders involved in the delivery of primary care.

Partners are a powerful vehicle for ensuring that the nation’s primary care workforce remains up to date on USPSTF recommendations. The complete list of partners is available in Appendices B and C.

## Efforts to Reduce Disparities in Healthcare

The Task Force is committed to promoting antiracism and health equity in preventive care by confronting these issues throughout its recommendation development process. Following the publication of its paper, “Actions to Transform U.S. Preventive Services Task Force Methods to Mitigate Systemic Racism in Clinical Preventive Services,”^28,29^ the USPSTF has worked to develop a health equity framework. This health equity framework is being used to help the Task Force more consistently approach the recommendation development for all populations that experience inequities in morbidity or mortality from disease, including but not limited to inequities related to race, ethnicity, sex, and gender.

The health equity framework provides a checklist of key items addressing how health equity issues can be approached at each phase of the USPSTF recommendation development process:

- Topic nomination, selection, and prioritization
- Work plan development
- Evidence review development
- Evidence deliberation
- Recommendation statement development
- Recommendation(s) dissemination

The Task Force has begun to evaluate these new approaches to its recommendation process across several topics. Experiences from the ongoing health equity pilot will inform both this framework and USPSTF priorities for additional areas of future methods work.

## Dissemination Impact of USPSTF Recommendations

The USPSTF engages in several activities to disseminate its recommendations to increase their uptake. During the past fiscal year (October 1, 2022, to September 30, 2023), clinicians, patients, and other stakeholders viewed the USPSTF recommendations via the USPSTF website, the Journal of the American Medical Association (JAMA), and the Prevention TaskForce app as follows:

## Efforts to Fill USPSTF Research Gaps

For each recommendation, regardless of whether the recommendation receives a letter grade or has insufficient evidence and receives an “I statement,” the USPSTF routinely calls attention to research gaps and highlights areas where evidence is needed for specific populations. The National Institutes of Health (NIH) considers these evidence gaps and often uses this information when developing future funding opportunities and other collaborative research efforts.

In 2020, AHRQ and NIH’s Office of Disease Prevention commissioned a National Academies of Sciences, Engineering, and Medicine report titled, “Closing Evidence Gaps in Clinical Prevention,” with two aims:

1. Propose a taxonomy to consistently describe evidence gaps in clinical prevention research.
2. Propose ways for research funders and guideline committees to facilitate research to close important gaps in prevention.

The objective of the report was to accelerate research to close important research gaps focusing on all three types of USPSTF recommendations (i.e., screening, behavioral counseling interventions, and preventive medications).^30^

As a result, AHRQ, NIH’s Office of Disease Prevention, and the USPSTF have been collaborating to improve how evidence gaps are classified, prioritized, and communicated. This effort yielded the development of a pilot design for articulating evidence gaps and future research needs in USPSTF recommendation statements. This work includes two processes to clearly communicate the most important gaps:

- The first process includes reviewing several public health criteria, including population effects, time urgency, adoptability, and equity, to determine research gaps for an individual recommendation topic.
- The second process includes using an expansion of the PICOTS (patient population, intervention, comparator, outcome, time, and setting) framework to provide more detail on key research studies that are needed to address the evidence gaps.

This work will be available on the USPSTF website in upcoming final recommendation statements. It will provide a systematic approach to classifying and prioritizing evidence gaps for funders and researchers, potentially reducing the time needed for study results to lead to improved health. In alignment with the USPSTF’s commitment to advancing health equity, the Task Force hopes this systematic approach to communicating evidence gaps for funders and researchers will improve filling evidence gaps that affect health inequities. The USPSTF will revise and finalize best practices for articulating evidence gaps and future research needs in the upcoming year.